# References

Depression Guideline Panel. Depression in Primary Care. Vol. 1, Diagnosis and Detection. Clinical Practice Guideline, No. 5, AHCPR Publication Number 93_0550. Rockville, MD: U.S. Department of Health and Human Services, Public Health Service, Agency for Health Care Policy and Research, April 1993.
Hayward, R.S.; Steinberg, E.P.; Ford, D.E.; Roizen, M.F.; and Roach, K.W. Preventive care guidelines: 1991. Annals of Internal Medicine. 1991;114.
Institute of Medicine. Growing Up Tobacco Free. Lynch, B.S., and Bonnie, R.J., eds. Washington, DC: National Academy Press, 1994.
U.S. Department of Health and Human Services. Preventing Tobacco Use Among Young People: A Report of the Surgeon General. DHHS Publication Number (CDC)94_0111. Atlanta, Georgia: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1994.