# The PEPS Process

In considering various programs for advancing the practice of substance abuse prevention, the advantages of a formal program to systematically assess available research and practice programs to provide recommendations to the field based on explicit criteria were clear. The PEPS Planning Group and staff developed the PEPS process for guideline development using the AHCPR documentation as a general model, with the following additions:

- Developing an explicit procedures manual and topic selection process
- Including vigorously sought practice evidence to determine the effectiveness of prevention activities
- Providing recommendations for research based on both the research and practice evidence
- Developing explicit recommendations for practice based on the quality of evidence and the knowledge of the expert panel members

As of 1996, the process has been applied to the present guideline and two others: Environmental Approaches for Preventing Problems Related to Alcohol Availability and Family-Centered Approaches for Preventing Substance Abuse Among Children and Adolescents.

The PEPS process, including the research and practice evidence search protocols and results, the rules of evidence for assessing the effectiveness of prevention strategies, and the SAMHSA/CSAP prevention framework, is explained in detail in the appendices. In brief, the development of a PEPS guideline generally follows these steps:

1. The Planning Group, which includes national experts in the field of substance abuse prevention, selects and defines a topic (from a list of topics recommended by the field) that meets explicitly stated criteria for development as a guideline.
2. A Federal Resource Panel, comprising representatives of agencies active in the prevention topic area, is convened to discuss the content of the guideline and to identify experts in the field who might serve on the Expert Panel. Expert Panel chairs and Panel members are also identified by staff and members of the Planning Group.
3. The Expert Panel meets to determine the scope and development of the guideline.
4. The staff search for relevant research and practice information, annotate their findings, and compile them by prevention approach for the Recommendations Subpanel of the Expert Panel.
5. A subpanel of the Expert Panel meets to apply the Rules of Evidence developed by the PEPS, arrive at summary judgments on the quality of the research and practice evidence by prevention approach, and provide recommendations to the field.
6. After the recommendations are written, staff prepare the full guideline for review by the Expert Panel.
7. The Expert Panel reviews the guideline, after which it is presented for review to the field.