# Context of This Guideline

SAMHSA and CSAP selected the guideline topic for several reasons. First, tobacco use among youth has been repeatedly documented as a priority public health problem. Two recent reports have vividly documented the problem and the state of prevention research and tobacco use by youth. The Surgeon General's 1994 report, Preventing Tobacco Use Among Young People, focused on youth tobacco use prevention as a public health priority (U.S. Department of Health and Human Services 1994). It and the Institute of Medicine's 1994 report, Growing Up Tobacco Free (Institute of Medicine 1994), recommended policy steps to prevent tobacco use by youth based on the effectiveness of those approaches. Second, focusing on underage smokers and users of smokeless tobacco also supports one of the goals identified in Healthy People 2000: National Health Promotion and Disease Prevention Objectives.

Finally, and most importantly, this guideline responds to the needs of the States in meeting the Synar Amendment to the 1992 Alcohol, Drug Abuse, and Mental Health Administration Reorganization Act. While most States have had laws restricting access to tobacco by minors, the laws have been poorly enforced. The Synar Amendment requires all States to document good-faith efforts to inhibit access by youth to tobacco products and report on their results each year. It requires that all States have a law prohibiting any manufacturer, retailer, or distributor of tobacco products from selling or distributing such products to any individual under the age of 18. The Synar Amendment also requires States to conduct annual random, unannounced inspections of a valid sample of youth-accessible outlets to ensure compliance with the law. The regulation requires States to submit to the Substance Abuse and Mental Health Services Administration an annual report detailing the State's activities to enforce the law, and its success during the previous fiscal year in reducing tobacco availability to youth, describing how inspections were conducted and the methods used to target outlets, and plans for enforcing the law in the coming fiscal year.

The Synar Amendment is a substantial complement to the August 1996 publication of the final rule on tobacco in the Federal Register mandating that the Food and Drug Administration regulate the sale and distribution of cigarettes and smokeless tobacco to children and adolescents. The rule prohibits the sale of cigarettes and smokeless tobacco to those under 18 years while leaving them on the market for adults. It restricts access by children and adolescents in the following ways: retailers must verify that purchasers are 18 years or older by checking identification; vending machine sales and self-service displays are prohibited except where retailers ensure that minors are not present at any time; mail-order sale of tobacco products will be monitored by the FDA; the minimum cigarette package size is 20 cigarettes; and the distribution of free cigarettes or smokeless tobacco samples is prohibited. The rule also includes restrictions designed to reduce the appeal of advertising to children and adolescents. For example, outdoor tobacco advertising is prohibited within 1,000 feet of elementary and secondary schools and public playgrounds. Cigarette and smokeless tobacco advertising is limited to black text on a white background except for publications with a primary adult readership and in adult-only facilities. The tobacco industry is prohibited from disseminating any nontobacco item or service that identifies that item or service with tobacco products, such as tee shirts, caps, and sporting goods. Also, tobacco companies are prohibited from sponsoring events using a brand name or logo that associates the event with particular cigarettes or smokeless tobacco.

Both the Synar Amendment and the FDA rule buttress the efforts of the National Center for Chronic Disease Prevention and Health Promotion at the Centers for Disease Control and Prevention, which has been active in efforts to modify risk factors regarding tobacco, nutrition, and physical activity and to encourage comprehensive prevention approaches, including school health education, community health promotion, and prevention centers. Their Office on Smoking and Health serves as a focal point for cigarette smoking and health activities. These include surveys and analyses of tobacco use and its impact, national public information and education campaigns, and distribution of technical and public information materials to the research and public health communities and the general public. The National Center also funds States to develop school health programs that target tobacco use and supports such State-based disease prevention and health promotion programs as smoking reduction programs.

Other related Federal Government activities include the National Institute on Drug Abuse, which produces numerous publications in prevention and treatment research, epidemiology, behavioral research, and health services research. These publications report on advances in substance abuse, identify resources, and promote an exchange of information among researchers, policymakers, practitioners, and administrators. Many publications address substance abuse prevention in general and prevention of youth tobacco use in particular; these include the NIDA Notes, the Clinical Report Series, and NIDA Research Monographs.

Although the accumulated knowledge and practice in substance abuse prevention present special challenges for developing systematic evidence-based guidelines, PEPS has benefited from earlier efforts by Federal agencies and professional medical societies in developing guidelines for medical practice. In 1957, the Federal Commission on Chronic Illness initiated the first known medical practice guideline, which reviewed the characteristics of a beneficial screening program. Since then, a number of programs have been developed for medical prevention, diagnosis, and treatment, including the Canadian Task Force on the Periodic Health Examination, the Medical Practice Committee of the American College of Physicians, and the United States Preventive Services Task Force. The purpose of these programs was primarily to improve the practice of clinical preventive care through evaluation of the effectiveness of preventive practices and to provide recommendations to physicians on the most effective practices. The Canadian Task Force first proposed explicit criteria for evaluating preventive interventions based on the evaluation design of the interventions themselves (Hayward et al. 1991).

The Agency for Health Care Policy and Research (AHCPR) updated the work of these programs through its Guideline Development Program, initiated in 1989. This program produces clinical guidelines designed to help health care practitioners determine how diseases and other conditions can be most effectively prevented, diagnosed, treated, and managed (Depression Guideline Panel 1993). AHCPR's approach has demonstrated the value of explicit rules of evidence for assessing research findings and the importance of defensible strategies for synthesizing credible information. In 1996, AHCPR published Smoking Cessation: A Guide for Primary Care Physicians as well as two companion documents: Smoking Cessation: Information for Specialists and You Can Quit Smoking: Consumer Guide.