# Preface

As part of an effort to strengthen the substance abuse prevention systems in the States and territories, the Center for Substance Abuse Prevention (CSAP) of the Substance Abuse and Mental Health Services Administration (SAMHSA) established the Prevention Enhancement Protocols System (PEPS) in 1992. It is a systematic process for evaluating prevention research and practice evidence, assessing the strength of that evidence, and then developing recommendations for practice. Prevention researchers, practitioners, State substance abuse decision- and policymakers, program planners, community practitioners, and concerned citizens can use this information to improve prevention programs, to consolidate and focus prevention interventions, and as a foundation for prevention studies. SAMHSA is pleased to present to the field Reducing Tobacco Use Among Youth: Community-Based Approaches, the first in a series of prevention guidelines planned by CSAP's Division of State and Community Systems Development.

The goals of PEPS include the following:

- Synthesizing research and practice evidence on selected topics
- Presenting recommendations for effective strategies in substance abuse prevention in a form suitable for various audiences
- Ensuring that PEPS products are optimally disseminated among target audiences
- Monitoring the use and relevance of PEPS products