# Tobacco Prevention Intervention: Implementation Action Plan

This chapter presents a generic action plan for implementing prevention interventions that practitioners, agencies, and community groups can adapt to meet the needs of specific target groups. Also discussed are cost and measurement issues to assist the practitioner in planning.

A systematic approach to implementing an intervention can help practitioners and community groups achieve desired goals.

## Conceptual Framework for Implementing Action Plan

The conceptual model that guides this action plan is based on the hypothesis that a systematic approach to implementing an intervention can lead to identified outcomes. This model focuses on attaining process (primary) outcomes, which are essential to achieving identified impact (secondary) outcomes within the target population. Five sequential process activities - the effective planning, organizing, delivering, monitoring, and evaluating of intervention activities - will result in the following primary outcomes (organized by process activity):

- Planning: Goals and Objectives Are Documented and Appropriate - Clearly defined goals and objectives that are appropriate for the target population form the foundation of an effective intervention.
- Organizing: Resources Support Goals and Objectives - Goals and objectives cannot be achieved unless resources are allocated appropriately.
- Delivering:
  - - Intervention Activities Support Goals and Objectives - Practitioners should monitor the intervention to ensure that each goal and its supporting objectives continue to address the intervention. Unforeseen changes in the community can hamper the intervention.
  - - The Target Population Receives the Intervention - Practitioners should monitor intervention activities to ensure that the intended target population receives the intervention.
- Monitoring:
  - - Data Are Collected on Attainment of Goals and Objectives - Practitioners should collect data on the intervention activities implemented for each goal and its objectives.
  - - Data Are Documented in Standard Format - A wide variety of data collection instruments are available to practitioners, allowing data to be shared with others and tracked through a standardized documentation trail.
  - - Data Are Reported - Practitioners should share data periodically with others in the prevention field and in their communities.
- Evaluating:
  - - Performance Is Assessed Regularly - Practitioners should view evaluation as an ongoing process, a management tool that is used to improve implementation.
  - - Performance Is Modified as Appropriate - Practitioners should finetune their interventions as data indicate to best achieve their goals and objectives.

The model further posits that interventions managed in this way will be more likely to effect the intended change in the target population.

## Application Issues for Practitioners

Presented here are issues in planning and evaluation that practitioners should consider when designing interventions to utilize the approaches reviewed in Chapter 3. Although these issues are by no means exhaustive, they are particularly relevant to planning effective tobacco use prevention interventions.

### Determine the Parameters of the Problem

Gather Baseline Data. Practitioners should determine the extent of tobacco use among youth. This information will help define target populations and program goals, objectives, and activities and determine which intervention is appropriate.

Identify the Target Group. Those at highest risk or the environment most in need of change should be identified through a community analysis or needs assessment. Insight should be obtained from adolescents regarding tobacco use through a small discussion or focus group. In addition, the practitioner should assess:

- The prevalence and patterns of tobacco use among youth in the community in question
- The community's knowledge, attitudes, and practices relating to youth and tobacco products
- The readiness for change in various sectors of the community: Who will work for and who will work against change?
- The ability of adolescents to purchase tobacco in the community
- The adequacy of school curricula designed to prevent tobacco use
- Activities to reduce tobacco use sponsored by the State health department and communities
- Barriers to tobacco use prevention programs in the community, which could include the following:
  - The community is not ready to support tobacco use prevention programs because community members do not consider tobacco use among youth to be a problem. - The tobacco industry engages in wellorganized strategies to promote tobacco use. - The community currently focuses its resources on other priorities, such as illicit drug use or lack of affordable housing, or it lacks the capacity or economic ability to engage in the necessary tobacco use prevention activities.

### Mobilize and Organize the Community

Each of the approaches reviewed in Chapter 3 requires some level of community involvement to be effective. Because communities vary in their capacity for involvement, practitioners should keep the following recommendations in mind when planning.

Community members and organizations should be involved in the early planning stages of the intervention through organizing a community group. Community groups appreciate being involved in decisions regarding program planning and intervention activities. Decisions regarding specific interventions, however, should be delayed until all information about the community (e.g., epidemiologic data and needs assessments) is available.

All organizations and individuals in the community with a stake in tobacco control, particularly those with credibility, expertise, and an understanding of target groups, should be identified. The array of organizations that represent diverse groups in the community, especially those that understand the needs of youth at high risk for tobacco use, should be invited to participate in the process. The roles that all participants are expected to fulfill, including the role of the lead agency, should be explained.

Community members and organizations should participate in the chosen intervention with active and specific roles. Practitioners should prepare materials for the community group that explain the specific steps of their involvement. Community members and organizations should be involved from the earliest stages of planning. Sustained, comprehensive community support makes the program part of the community and provides the structure necessary for sustained success. A vital community partnership should include the following elements:

- Prominent individuals and community leaders
- Representatives of the community's ethnic groups
- Community businesses, merchants, and organizations
- Students and student organizations
- Representatives of the school system
- Parents and other concerned community members
- Government agencies
- Social agencies and associations
- Mayor's office
- Police and the judicial system

### Define Program Goals and Objectives

Once a profile of the problem in the community is compiled, target groups should be selected and goals and objectives defined based on the community's needs. Goals should be realistic and specific and should include the following elements:

- Who? The target group for change
- What? The action or change expected
- How much? The extent of change expected
- When? The time frame for change

### Select Prevention Approaches, Interventions, and Activities

The six prevention approaches described in Chapter 3 should now be reviewed to determine which are appropriate for the targeted population and which best support the goals and objectives. The interventions selected should actively involve the target population and include an array of activities. Each approach should be reviewed carefully and, before an approach is selected, special attention given to the level of evidence of effectiveness and the lessons learned and recommendations.

Once an approach is selected, suggested activities that will be most helpful in meeting the objective for that intervention should be chosen. The planning group can be called on to develop additional activities that contribute to the achievement of identified goals. The chosen intervention should include activities that support the stated goals and objectives. The intervention or combination of interventions should be tailored to the needs of the community and to the stated goals and objectives. Creativity should be exercised in selecting or designing activities to deliver the intervention.

The new initiatives should be linked to existing programs or activities whenever possible. This approach has several benefits:

- Prevention activities become part of existing networks.
- The likelihood of local acceptance and support is increased.
- Costly duplication of services is avoided.
- A valuable partnership with key community members is developed.

Existing materials should be used whenever possible to save time and funds. A wealth of effective printed and audiovisual prevention materials, much of which is in the public domain, is available on request.

Prevention of smokeless tobacco use should be included in the intervention. In one study, more than 15 percent of nonsmokers and 32 percent of smokers reported using smokeless tobacco during the past month.

The need for programs to help nicotinedependent youth quit should also be considered. Unfortunately, conventional primary prevention ("don't ever start") or conventional secondary prevention (encouraging people to quit) may not be sufficiently powerful or comprehensive to break nicotine dependence. Special programs for nicotinedependent youth should become a part of all comprehensive tobacco control programs.

### Plan To Implement the Intervention

To facilitate the implementation of the interventions reviewed in this guideline, practitioners should incorporate the following steps into their planning process.

First, determine all needed and available resources, not only for the lead agency, but also for the community group, to deliver the intervention. Resources available through the lead agency should be determined, in addition to those available elsewhere in the community. For example, if the intervention chosen is reducing youth access to tobacco and one of the activities is purchase attempts with incentives to merchants, a commercial organization that is a member of the community group may be willing to provide incentives free of charge.

Second, identify funding sources to support the intervention. There are a number of Federal, State, and private sources of funding for tobacco use prevention programs. Practitioners should determine the range of funding opportunities available and collaborate with other agencies with similar agendas for tobacco use prevention.

### Monitor and Evaluate the Effectiveness of the Intervention

Simple data collection and evaluation methods are appropriate to assess the effectiveness of the reviewed approaches, particularly when practitioners consider the following recommendations:

- Efficiently collect and manage data:
  - Document the implementation of the intervention as planned, including progress reports and lists of participating individuals and organizations and the activities implemented - Document achievement of goals and objectives by conducting surveys to measure attitudes and tobacco use among youth - Gather data continuously in a standard format
- Determine the effectiveness of the implemented intervention, particularly:
  - - Whether the intervention was implemented as planned, the target population was reached, and the goals and objectives were attained
  - - Whether the program had the anticipated effect on the target population

Insights should be obtained into the effectiveness of prevention approaches. If the intervention does not achieve its stated goals and objectives and the anticipated changes in the target population are not seen, practitioners can provide valuable information, such as barriers encountered in simplementing the intervention. Documenting this information for other practitioners, researchers, and State and Federal agencies will help improve efforts to reduce tobacco use among youth.

Prevention efforts must be a sustained process, not a single event or campaign. Success in prevention depends on continually assessing and improving interventions. The norms and culture of adolescents are in a constant state of change, and prevention efforts must quickly adapt. If the effort is to be sustained over time, the community partnership must be continually revitalized with new members.

## Cost Considerations

Conducting extensive prevention interventions is expensive in terms of both monetary and human resources. In general, community groups do not have adequate resources to support all the activities of multicomponent interventions. By following the guidelines described earlier in this chapter, community organizations will have identified existing efforts in a geographic area and will be able to design activities that complement those efforts. If local activities are few, community organizations can contact schools, local and State health departments, and substance abuse/mental health departments to determine the types of activities that would complement local and State agency plans for tobacco use prevention. Communities and State substance abuse agencies should contact the State agency responsible for tobacco control activities, usually the Department of Health. All States now have funding for tobacco control activities, including prevention, through the ASSIST or IMPACT programs.

The resources needed vary considerably with the approach and are often dependent on the level of sophistication of the planned intervention. Community groups can reduce costs by using existing materials, involving community members (especially youth) to volunteer for staff duties, and planning a practical, simple activity. An agency or community wishing to apply for funding should be prepared to write a proposal. Many proposals require documented answers to the planning, implementation, and evaluation issues presented above.

## Cost Considerations

### Recommended Evaluation Designs

Because many of the approaches recommended in this guideline have already been assessed on all evaluation levels, communities and local and State agencies need not make sophisticated designs to evaluate them. In following the generic implementation plan presented here, however, practitioners and community groups can add an evaluation component to document the delivery and impact of their intervention during the first process activity - planning. A simple evaluation to determine the effectiveness of an approach within a target population might include a design with baseline and followup measurement of the target population. Such a design would provide for evidence of change within the target population with a minimum of resource investment. In fact, by following the steps within the five process activities outlined here - planning, organizing, delivering, monitoring, and evaluating - this simple evaluation will have been completed. Another type of simple evaluation is a selfcomparison. In this case, a community that implements an approach compares itself on appropriate measures with a community that is similar but has not adopted the approach.

### Threats to Internal Validity

When a program evaluation is conducted, regardless of the rigor of the evaluation design, the evaluators must consider factors other than the intervention that might account for the outcome. These factors, termed threats to internal validity, diminish the likelihood that an observed outcome is attributable to the intervention. The threats to internal validity that are most likely to affect simple evaluation designs are as follows:

- Selection - A selection bias results when certain individuals or groups are, knowingly or unknowingly, selectively included or excluded from the intervention or comparison community. For example, a community may decide to implement a retailerdirected intervention and evaluate the effects of the approach through a comparison with another community. If the comparison community already has a low rate of tobacco purchases by minors, a selection bias will render it difficult to assess the effects of the intervention.
- Measurement - A measurement bias occurs when the measures selected are not reliable or valid. This generally occurs when individuals are surveyed and asked to give information about past behaviors or feelings or when measures are used that have not been proven in research.
- Confounding - A confounding bias occurs when an observed relationship between intervention A and outcome B can be attributed to a third factor, C, which is related to both A and B. In other words, there is a weak or nonexistent relationship between A and B and the explanatory relationship between A and C or between B and C. Age, ethnicity, gender, and socioeconomic status are common confounding factors.
- An example based on the approaches reviewed here might be when a schoollinked parental intervention demonstrates that children of parents who received the intervention have a lower smoking rate at 2 years after the intervention than do their peers. If those children were primarily African American and the comparison children were primarily white, this finding would be confounded by ethnicity, because African American adolescents are less likely than white ones to use tobacco. In this case, the results could not necessarily be attributable to the intervention.
- Intervention Contamination - When a control community is used to evaluate the effect of an intervention, and the intervention and comparison communities are geographically close, the comparison community may be unintentionally exposed to the intervention. This type of bias is called intervention contamination and is most likely when counteradvertising is chosen as the intervention approach. Counteradvertising generally involves broadcast media, which can be received in nearby communities.
- Randomization or Blinding of Observers - Individuals who interview respondents or make observations should not know whether the respondent has received the intervention. Interviewers who are aware of the respondent's exposure to the intervention may make biased observations. For example, an adolescent recruited to attempt to purchase cigarettes at a retail outlet who is aware that the owner and clerk have been exposed to a retailer intervention may be influenced to be more or less vigorous in the purchase attempt than he or she would otherwise have been.
- History - A significant, unplanned State, local, or other event during the intervention could affect the measured outcome. For example, if a State were to assess the effect of increasing the sales tax on cigarette sales to minors during the implementation of the final Synar Regulation, it might appear that the new tax had affected cigarette sales when in fact, implementation of the new regulation had done so.
- Testing or Observation - Participants' behavior regarding study outcomes can change when they are tested or observed too frequently. The retailerdirected approaches that require observation of clerks and owners thus might result in a testing bias. If the clerk is aware that the purchase attempt is for survey or enforcement purposes, he or she may be less likely to sell to the adolescent.

A positive result can probably safely be attributed to the implementation of the intervention if none of the above threats to internal validity applies. Although one can never be certain that outside factors did not affect the outcome, particularly when a simple evaluation was used, practitioners who follow a sound action plan and consider and rule out alternative explanations may place confidence in the achieved results.

## Measurement Considerations

Appropriate data collection is important to the advancement of effective prevention strategies. Researchers and practitioners utilize various measures to gauge the effectiveness and outcomes of interventions. Practitioners and community groups can choose measures appropriate to the approach chosen. Below are presented simple measures for each approach reviewed in this guideline.

### Economic Interventions

The primary purpose of economic interventions is to increase the cost of tobacco products. Thus, passing and sustaining a policy or regulation that increases taxes on tobacco products would usually be the outcome of interest for this approach.

### Counteradvertising

The intended outcome of counteradvertising is to change youths' perceptions regarding tobacco use. Measures appropriate to assess this approach include their level of knowledge about the extent of tobacco use among their peers and their attitudes about the tobacco industry and tobacco use as a part of growing up.

### Retailer-Directed Interventions

Interventions directed at tobacco retailers are intended to reduce minors' access to tobacco by changing the sales practices of tobacco merchants. Measures appropriate for this approach include the level of merchant and clerk awareness concerning sales of tobacco to youth and the purchasability of tobacco by youth in retail outlets.

In addition to deciding among measures of purchasability, practitioners and community groups should consider involving minors in this activity. Nearly all preventionists agree that to establish the prevalence of illegal sales to minors, minors must be recruited to make the purchase attempts. Minors who are enthusiastic about participating in this process can generally be found through the school system. The protection of minors, however, should be ensured through the following precautions:

- All minors should work under the direction and supervision of an adult.
- The adult should drive the minor to the purchase attempt site and establish that it is safe to make the purchase attempt.
- Minors should receive complete training in the purpose and procedures of the activity.
- The protocol for the attempted purchase activity should include parental consent and legal protection of the minors.
- The minor should be discouraged from persisting in the purchase attempt if the clerk refuses the sale.
- Minors should be instructed to tell the truth about their age if asked and to say that the tobacco product is "for me" if asked.
- Minors should be instructed not to attempt the purchase if someone they know is working or present in the outlet.

### SchoolBased Interventions

Appropriate measures for schoolbased interventions are presented below by cluster, as were the interventions themselves in Chapter 3.

Parental Involvement. Appropriate measures for parental involvement include the number of parents who discuss tobacco use with their children, the number of children who report parental discussion of tobacco use, and the completion rate for homework assignments regarding tobacco use that require children to involve their parents in the assignment.

Student Activism. Appropriate measures for student activism include the number of adolescents who become involved in antitobacco activities, the level of student knowledge regarding the problems that result from tobacco use, and student attitudes toward the tobacco industry and tobacco use.

Media. Interventions that involve media messages to complement school curricula should be assessed according to the number of messages and time of day of message delivery, the extent to which parents and students were exposed to the messages, and whether the messages actually complemented the school curricula.

### Tobacco-Free Environments

The objective of establishing tobaccofree environments is to increase the number and types of environments that do not expose children and adults to tobacco products. Thus, measures of this approach include the successful passage of policies and regulations to limit the types of environments in which tobacco can be used and the enforcement of these policies and regulations.

### Advertising and Promotion Restriction Interventions

Measures of the success of restrictions on advertising and promotion include the passage of legislation that restricts the placement of tobacco advertisements and promotions of events and the adoption of policies by organizations not to accept money from the tobacco industry to fund public and private events. Another positive measure is the identification and procurement of alternative sources of funding to support activities and events.

### Estimating the Incidence and Prevalence of Adolescent Tobacco Use

Practitioners and community groups can use the measures presented above to determine the immediate impact of the implemented approach. It is also recommended that practitioners and community groups continuously collect data on the incidence and prevalence of tobacco use in their communities and States to monitor changes in tobacco use among youth following the intervention.

In this document, the term tobacco use is used to refer to the use of cigarettes and/or smokeless tobacco. We recommend that practitioners measure the use of both of these products in their adolescent populations. To measure incidence, or age at first tobacco use, the following questions are recommended:

- How old were you when you smoked a whole cigarette for the first time?
- How old were you when you used snuff or chewing tobacco for the first time?

To measure prevalence, or current use of tobacco, each of the following questions should be included in a survey:

- Have you only smoked cigarettes in the past 30 days?
- Have you only used smokeless tobacco in the past 30 days?
- Have you used both cigarettes and smokeless tobacco in the past 30 days?
- During the last 30 days, on how many days did you smoke cigarettes?
- During the last 30 days, on how many days did you use snuff or chewing tobacco?

Practitioners and community groups can estimate the prevalence of tobacco use in the adolescent population as the combined total of these three measures: Any use in the past 30 days? Daily use in the past 30 days? Lifetime use? Asking all three questions allows the practitioner to measure all tobacco use in the population accurately and to plan an intervention that targets the use of cigarettes or smokeless tobacco or both. In addition, to make intervention planning more effective, it is recommended that practitioners and community groups collect genderspecific data, given the differences in use of cigarettes and smokeless tobacco by boys and girls.

## Summary

Those who follow the planning, implementation, and evaluation process presented here to implement the approaches reviewed in Chapter 3 are likely to be successful in reducing tobacco use among youth. Practitioners, policymakers, and researchers are encouraged to use systematic protocols or action plans to confront the challenge of reducing tobacco use among the nation's youth.

## References

Office for Substance Abuse Prevention. Cultural Competence for Evaluators. OSAP Cultural Competence Series, Vol. 1. Orlandi, M.A., ed. DHHS Pub. No. (ADM)92_1884. Rockville: U.S. Department of Health and Human Services, Public Health Service, Alcohol, Drug Abuse, and Mental Health Administration, Office for Substance Abuse Prevention, 1992.
Patton, M.Q. Practical Evaluation. Newbury Park, CA: Sage Publications, 1989.
Windsor, R.A.; Baronowski, T.; Clark, N.; and Cutter, G. Evaluation of Health Promotion, Health Education and Disease Prevention Programs. Mountain View, CA: Mayfield Publishing, 1994.