# Analysis and Recommendations

At first glance, the questions "Does prevention work?" and "Is this intervention effective?" appear to be simple queries warranting simple responses.

Deeper reflection, however, reveals that thoughtful answers to these questions are possible only after a systematic and rigorous evaluation of both the research and practice evidence. These simple questions address nothing less than the heart of the scientific method, the soundness of research and practice methodologies, and the scope of existing evidence. To help prevention practitioners and community groups choose prevention approaches that are most likely to curb adolescent tobacco use in their community, this chapter evaluates six community-based prevention approaches:

1. Economic interventions
2. Counteradvertising
3. Retailer-directed interventions
4. Multicomponent school-linked community approaches
5. Tobacco-free environment policies
6. Restriction of advertising and promotion

Determining the effectiveness of prevention approaches requires a systematic evaluation of research and practice evidence.

## Organization of This Chapter

The primary goal of this chapter is to provide prevention planners with an understanding of the effectiveness of these approaches and offer practical recommendations and suggestions. To that end, this chapter has two major sections: Analysis of Evidence and Recommendations for Practice.

### Analysis of Evidence

The first major section, Analysis of Evidence, presents a systematic and rigorous examination of research studies and practice cases that provide evidence for the six prevention approaches. It includes conclusions drawn from the evidence, the strength of the evidence, lessons learned from the evidence, and suggestions for future research endeavors.

The evidence has been analyzed according to a systematic protocol by a Prevention Enhancement Protocols System Expert Panel of researchers and practitioners with expertise in tobacco use prevention (see Appendices A, B, and C).

### Recommendations for Practice

The second major section of this chapter builds on the knowledge base presented in the Analysis of Evidence and expands it to include the professional expertise of the Prevention Enhancement Protocols System (PEPS) Expert Panel members. It consists of their suggestions, recommendations, observations, and interpretations. These recommendations are based on the evidence presented in the first section, additional evidence not reviewed there, and the panel members' research and practice experience and opinions. The purpose of the section is to facilitate transfer of practical information from the Expert Panel to those involved in substance abuse prevention on the State, regional, and local levels.

### Defining Evidence and Prevention Approaches

The term research evidence refers to the body of knowledge gained from research on particular topics. The basis of this information is investigations whose designs range from experimental to quasi-experimental to nonexperimental. The term practice evidence describes information gained from prevention practice cases, generally compiled in the form of case studies, which often include process evaluation information on program implementation and procedures.

A prevention approach is defined as a group of prevention activities that broadly share common methods and strategies, assumptions (theories or hypotheses), and outcomes. Two of the six prevention approaches reviewed and presented in this chapter were sufficiently broad to have identifiable subsets, each with its own emphasis or focus. These subsets of prevention approaches are referred to as clusters.

## Organization of the Evidence Into Approaches

During the evaluation phase of developing this guideline, the research and practice evidence was grouped into six prevention approaches:

### Prevention Approach 1: Economic Interventions

Increases in taxes on tobacco products are economic interventions designed to prevent the initiation, delay the start, or decrease the level of tobacco consumption by adolescents. Economic interventions include increases in Federal and State tobacco taxes.

### Prevention Approach 2: Counteradvertising

Adolescents develop tobacco-related attitudes, beliefs, and behaviors as the result of influences from advertising, media, peers, and other sociocultural sources. Counteradvertising interventions are designed to change adolescents' perceived norms regarding tobacco use. These interventions involve negative messages about using and positive messages about not using tobacco, information about tobacco industry manipulation, and refusal skills. Mass media campaigns are the most common examples of counteradvertising.

### Prevention Approach 3: Retailer-Directed Interventions

A primary source from which adolescents obtain tobacco products is retail tobacco outlets, such as convenience and grocery stores, service stations, and pharmacies. Interventions directed at tobacco retailers are designed to reduce access to tobacco products by adolescents at retail outlets. Interventions within this approach were classified into three clusters.

The first cluster relates to merchant and community education about tobacco use by adolescents and about the laws prohibiting tobacco sales to minors. Interventions in this cluster typically involve educational programs designed to teach merchants, clerks, and the general public about tobacco use by adolescents, the local laws prohibiting tobacco sales to adolescents, and the responsibility of merchants to comply with the laws.

The second cluster involves the enactment of laws prohibiting tobacco sales to minors. These generally involve local or State laws prohibiting the sale of tobacco products to individuals under a specific age, with penalties for merchants and clerks who violate the laws. This cluster also includes laws requiring locking devices on cigarette vending machines.

The third cluster consists of interventions that involve the enforcement of laws prohibiting tobacco sales to minors combined with interventions in the first cluster. Interventions in this cluster often involve purchase attempts by adolescents in cooperation with enforcement officials, followed by publicity about the results of the purchase attempts and the legal consequences to merchants. Interventions may include strengthening existing tobacco sales laws or increasing penalties for violating them. They may also include efforts designed to remind merchants and clerks of the laws, such as providing copies of the laws and warning signs in stores.

### Prevention Approach 4: Multicomponent School-Linked Community Approaches

Community interventions, especially comprehensive community-based prevention programs, typically have two or more components. These components may have different target audiences, goals, and approaches. Included here is a review of multicomponent community approaches that involve school-based interventions combined with at least one of three components: parent involvement, student activism, and the media. These components were also organized into three clusters.

The first cluster relates to multicomponent prevention efforts that utilize parental involvement as a component of school-based programs. These efforts include parent surveys, take-home quizzes for parents and students, letters to parents, self-help materials, parent training, community organizing regarding school policy and curricula, and media campaigns.

The second cluster involves student activism as a component of multicomponent prevention programs. In this context, student activism means student antitobacco activities such as writing letters to movie producers and magazine editors to protest tobacco advertising, to sports figures to ask them to avoid endorsing tobacco products, and to restaurant owners to advocate smoke-free restaurants. Student activism also includes antitobacco poster contests, skits, songs, art projects, and parade floats.

The third cluster focuses on the use of media-based prevention components within multicomponent prevention programs. In this context, the term media refers to mass media (e.g., television, radio, and print), small media (e.g., newsletters and local newspapers), and other written information (e.g., pamphlets, curricula, and articles).

### Prevention Approach 5: Tobacco-Free Environment Policies

Adolescents are exposed to secondhand tobacco smoke in environments that allow tobacco use. Also, adolescent tobacco users may use tobacco in environments that do not prohibit tobacco use. A tobacco-free environment policy as a prevention approach is one that restricts tobacco use in public. Intervention activities include provision of technical assistance for developing a tobacco-free environment policy, and education about existing law and policies.

### Prevention Approach 6: Restriction of Advertising and Promotion

Adolescents are exposed to a deluge of protobacco influence via popular culture, mass media, and tobacco industry marketing. In particular, tobacco sponsorship of sporting and cultural events provides opportunities to promote tobacco use and to link tobacco use with sports achievements. With this in mind, the prevention approach of advertising and promotion restriction includes interventions such as threatening to protest tobacco industry-sponsored events, developing policies that prohibit tobacco sponsorship of events, finding alternative sponsorship for events, promoting tobacco-free events, and providing tobacco-free messages within sports education.

## Analysis of Evidence

This section presents the results of the Expert Panel's analysis of the research and practice evidence for each of the six prevention approaches. Each prevention approach is reviewed and presented in a standardized format that allows the reader to systematically examine them and to understand their similarities, differences, and purposes. The elements of this standardized format are described in the following paragraphs.

- Intended Measurable Outcomes
- Each prevention approach is accompanied by a brief statement about the intended measurable outcome - the overall expected consequence and the results of all interventions within each approach. Because intended outcomes should be quantifiable, they are described as intended measurable outcomes.

- Conceptual Framework
- Each prevention approach includes a synopsis of the philosophical basis for the approach. This is the assumed reasons or hypotheses that explain why the interventions in a specific approach should have a given effect. This section may also include a brief statement about the context of the prevention approach.

- Objectives of Studies Reviewed
- This section includes a partial list of the objectives of the individual research studies and practice cases that were reviewed for a prevention approach. The objectives are the specific changes expected as the result of the interventions being reviewed.

- Activities of Studies Reviewed
- This section includes a partial list of activities that were employed to meet the interventions' objectives. These include individual components of the interventions.

- Basis of Evaluation of Evidence
- This section provides a brief abstract of each research study and practice case, including the study design, where appropriate; the overall intent of the study or practice program; and selected findings or results that are most relevant to the prevention approach in question. Although the PEPS Expert Panel carefully examined the design of research studies and the process evaluation information of the practice cases, the abstracts do not include this information. Thus, these summaries are not critical analyses of study design, threats to internal validity, or program implementation. Studies that had severe deficiencies were excluded from the pool from which the recommendations were derived. The summaries of studies presented simply provide a snapshot of the research or practice evidence. When known, the time lines or chronologies of the intervention and study are included in the abstract.

- Level of Evidence
- Each of the prevention approaches or clusters is followed by a shaded box titled Level of Evidence. These provide two important pieces of information. First, they describe conclusions that can be drawn from an analysis of the research and/or practice evidence for each approach (or cluster). Second, they indicate the strength of the level of evidence supporting the conclusions. The criteria for assigning the levels of evidence are as follows:

1. Strong Level of Evidence

a. Consistent, positive results of strong or medium effect from a series of studies, including:
  - At least three well-executed studies of experimental or quasi-experimental design OR
  - Two well-executed research studies of experimental or quasi-experimental design AND
  - Consistent results from at least three case studies
b. The use of at least two different methodologies
c. Unambiguous time ordering of intervention and results
d. A plausible conceptual model ruling out or controlling for alternative causal paths or explanations

2. Medium Level of Evidence

a. Consistent, positive results from a series of studies, including:
  - At least two well-executed studies with experimental or quasi-experimental designs OR
  - At least one well-executed study and three prevention case studies showing statistically significant or qualitatively clear effects
b. The use of at least two different methodologies
c. Unambiguous time ordering of intervention and results when so measured

3. Suggestive but Insufficient Evidence

This category is used to describe research and/or practice evidence that is based on a plausible conceptual model or on previous research and is being demonstrated in rigorous evaluation studies or appropriate intervention programs in process. One of two conditions typically causes evidence to be described as suggestive but insufficient:

a. In the first condition, the evidence, although limited, appears to support a conclusion, but additional research is needed to fully support the conclusion. This condition often applies to areas in which there has been little study, such as those that are impractical to research or new areas of study.
b. A second condition involves equivocal results. In this condition, a specific conclusion is supported in some studies but is not supported in others. The first three categories for level of evidence provide a means to present research and practice evidence for which there are varying degrees of confirmation of positive effect.

4. Substantial Evidence of Ineffectiveness

This fourth category describes research and practice evidence that demonstrate a prevention approach is not effective. The criterion for inclusion in this category is the absence of a statistically significant effect or a statistically significant negative effect in a majority of well-executed studies, including at least two quantitative studies with sample sizes sufficient to test for the significance of the effect.

### Lessons Learned From Evidence Reviewed

This section describes lessons learned and conclusions reached from the research and practice evidence reviewed for an approach. The basis of these is the research and practice evidence reviewed and summarized for an approach.

### Recommendations for Future Research

Each prevention approach includes recommendations and suggestions from the Expert Panel for future research endeavors.

### Information Not Included

Although this guideline reviews and evaluates many multicomponent prevention programs that include a school component, it does not examine the effectiveness of programs that are exclusively school based. Two notable federally produced documents thoroughly review school-based prevention programs for the prevention of youth tobacco use. These are Preventing Tobacco Use Among Young People: A Report of the Surgeon General (Surgeon General of the United States 1994) and Growing Up Tobacco Free: Preventing Nicotine Addiction in Children and Youths (Institute of Medicine 1994).

Similarly, this document does not provide an exhaustive review of all types of practice programs currently in use. All research and practice evidence had to meet rigorous qualitative criteria to be included in the guideline. While more than 80 prevention programs were reviewed, many did not satisfy the criteria. For example, many practice programs did not sufficiently document process evaluation activities.

### Multiple Use of Research Studies

Many tobacco prevention programs for adolescents have multiple components. As a result, a single study of a multicomponent intervention may provide evidence regarding more than one prevention approach. For example, a program that includes media-based counteradvertising components and merchant education activities may provide evidence regarding two prevention approaches: counteradvertising and retailer-directed interventions. Accordingly, some studies are used as evidence in more than one prevention approach.

## Prevention Approach 1: Economic Interventions

### Intended Measurable Outcome

To prevent the initiation, delay the onset, or decrease the level of adolescent tobacco consumption by increasing the sales tax on tobacco products

### Conceptual Framework

Sensitivity to tobacco price fluctuations tends to be high among adolescents. Therefore, increasing the price of tobacco products should reduce adolescent tobacco purchases and thus reduce the initiation, delay the start, or decrease the level of tobacco consumption by adolescents. Substantial tobacco tax increases result in higher retail tobacco costs.

### Objectives of Studies Reviewed

- To assess the elasticity of adolescent demand for cigarettes based on differing decreases or increases in the Federal excise tax
- To compare changes in tobacco consumption in States where there were tax increases to those in States where there were no tax increases
- To identify the likely effects of increases in cigarette excise taxes on the number of adolescent smokers

### Activities of Studies Reviewed

- Increase in Federal taxes
- Increase in State taxes
- Legislative changes
- Media campaigns

### Basis of Evaluation of Evidence

The following analysis of the effectiveness of economic interventions to prevent the initiation, delay the start, or decrease the level of tobacco consumption by adolescents is based on four econometric studies (Glantz 1993; Peterson et al. 1992; U.S. General Accounting Office 1989; Warner 1986).

Glantz (1993) conducted a quasi-experimental time series study to examine the effect of the California law, based on Proposition 99, that required a 25-cent tax increase on cigarettes and allocated 20 percent of the resulting revenues to a Health Education Account for a statewide tobacco education effort. The study was designed to evaluate whether the California law had an effect on tobacco consumption, tobacco pricing, and tobacco industry revenues.

Findings:

1. Enactment of Proposition 99 resulted in a tripling of the rate at which cigarette consumption had been falling.
2. Although tobacco price increases caused a drop in tobacco consumption nationwide, tobacco consumption declined faster in California than elsewhere in the United States.
3. Tobacco industry advertising in California increased by 50 percent.

The purpose of a study by Peterson et al. (1992) was to evaluate the effects of State cigarette tax increases on cigarette sales in the 50 States for the years 1955 to 1988. In this historical cohort design study, they compared changes in cigarette consumption in States during years in which there were State cigarette tax increases with consumption changes during years when there were no tax increases. They also assessed changes in cigarette consumption as a function of the size of State tax increases and compared the effects of State tax increases on cigarette consumption during three time periods: 1955 through 1964 (prior to the Surgeon General's first report on smoking), 1965 through 1978 (when per capita cigarette consumption peaked), and 1979 through 1988 (a period of declining consumption).

Findings: Cigarette sales decreased by an average of three packs per capita following a tax increase.

1. Cigarette sales increased by 0.6 packs per capita with no tax increase.
2. For each 1-cent increase in cigarette taxes, cigarette sales fell by 0.75 packs per capita.

Based on findings from previously conducted research, an analysis of the economic literature on adolescent smoking by the U.S. General Accounting Office (GAO) (1989) was designed to estimate the impact of increasing the Federal cigarette excise taxes on the number of teenage smokers. The study was also designed to determine the extent and consequences of teenage smoking. The analysis was based on (1) the 1989 Surgeon General's Report; (2) the 1982 and 1985 National Household Surveys on Drug Abuse; (3) the 1987 High School Seniors Survey; (4) numerous economic studies of smoking, especially those that estimate the price responsiveness of teenagers' smoking behavior; (5) interviews with the authors of these studies; (6) interviews with officials of the National Center for Health Statistics; (7) interviews with officials of the Office of Smoking and Health at the Centers for Disease Control and Prevention; (8) information about cigarette prices published by the Tobacco Institute; and (9) a recent GAO report on Federal cigarette excise taxes.

Findings:

1. The investigators estimated that if excise taxes were raised about 20 cents per pack, the likely result would be more than 500,000 fewer smokers and 125,000 fewer premature deaths.

The goal of an econometric analysis by Warner (1986) was to determine whether changes in the Federal cigarette excise tax would affect the number of adolescents and adults who smoke cigarettes. In particular, this study estimated the potential effect of an increase or a decrease in the Federal cigarette excise tax as measured by the numbers of adolescents and adults who would be encouraged to start smoking, continue smoking, not start smoking, or stop smoking.

Findings: An 8-cent tax decrease would induce 1.9 million Americans to smoke who would not do so if the tax were to remain at 16 cents - including more than 460,000 adolescents who would begin or continue smoking.

1. An 8-cent tax increase would encourage 1.8 million Americans, including more than 400,000 adolescents, to quit or not begin smoking.
2. A 16-cent tax increase would encourage nearly 3.5 million Americans, including more than 800,000 teenagers and nearly 2 million young adults aged 20 to 35 years, to quit or not begin smoking.

### Lessons Learned From Evidence Reviewed

- Tobacco tax increases are effective in reducing the prevalence of tobacco use by adolescents. Efforts to increase State taxes on tobacco products have included the mobilization of community groups, other groups, and legislators. Depending on the State, taxes can be increased through the initiative or the legislative process.
- Although tobacco tax increases will decrease the prevalence of adolescent tobacco use, other prevention activities must be utilized to sustain such decreases. Tobacco tax increases are most effective within a comprehensive, multicomponent prevention program.
- The benefits of increases in tobacco taxes, such as reduction in adolescent cigarette use, will shrink as inflation erodes the real value of the tax increase - unless the excise tax is indexed so that the nominal tax rate (expressed in cents per pack) rises in step with prices. Indexing tobacco taxes to the consumer price index or to the wholesale price of cigarettes would make permanent the public health gains of higher taxes.

Level of Evidence

The research evidence reviewed indicates that laws can be established or modified to increase Federal or State taxes on tobacco products:

There is strong evidence that instituting tobacco tax increases is an effective approach to reduce the prevalence of adolescent tobacco use, especially when the tax is sufficiently high and is linked to the consumer price index.

### Suggestions for Future Research

- When tax increases are implemented, an effort should be made to study the potential effect on youth consumption, including the establishment of baseline evaluations to accurately assess changes after implementation.
- In addition to tobacco tax increases, it would be valuable to research and develop alternative economic approaches to tobacco growing and tobacco production.

## Prevention Approach 2: Counteradvertising

### Intended Measurable Outcome

To change perceived norms among children and adolescents regarding tobacco use

### Conceptual Framework

Research and experience demonstrate that adolescents develop attitudes, beliefs, and behaviors regarding tobacco use from peers, family members, television, and other cultural sources. Adolescents often have the perception that tobacco use among their peers is common and acceptable. They are also exposed to messages through advertising that links tobacco use with peer acceptability, success, and fun. Media messages promoting negative images about tobacco use, revealing the actual prevalence of tobacco use among youth, and providing information about the unacceptability of tobacco use should help to change perceived norms among adolescents about tobacco use.

### Objectives of Studies Reviewed

- To increase the exposure of children and adolescents to negative messages about tobacco use or positive messages about not using tobacco
- To increase adolescents' ability to identify hidden messages in tobacco advertising and their awareness of marketing manipulation
- To change adolescents' attitudes and beliefs about tobacco use and determine the frequency and types of media messages that will be most effective in changing perceived norms
- To increase adolescents' awareness of norms regarding smoking
- To improve adolescents' tobacco refusal skills and help them develop smoking cessation skills

### Activities of Studies Reviewed

- Radio and television campaigns
- Multilevel mass and small media campaigns, including billboards, posters, magazines, radio, and television
- A mass media campaign linked with youth education programs
- Prime time airing of media campaigns
- A Statewide multimedia tobacco education media campaign

### Basis of Evaluation of Evidence

The analysis of the effectiveness of counteradvertising in changing perceived norms among children and adolescents regarding tobacco use is based on five research studies (Bauman et al. 1991; Flynn et al. 1992, 1994; McKenna and Williams 1993; Popham et al. 1994; Murray et al. 1994).

A study by Bauman et al. (1991) had a quasi-experimental design using cross-sectional measurements. The study's goal was to evaluate the impact of three mass-media antismoking campaigns directed at adolescents 11 to 17 months after the broadcasts ended. The first campaign involved eight 30-second radio messages that focused on seven expected consequences of smoking related to whether young people become regular smokers. The second campaign featured a 60-second radio message that invited youth 12 to 15 years old to enter a sweepstakes. Once entered, they received brochures asking them to talk to their friends about not smoking, encourage them to pledge not to smoke, and have them enter the sweepstakes, with financial incentives for recruiting friends. The third campaign comprised a television broadcast of the sweepstakes offer and only three of the radio messages. The study was designed to assess whether the campaigns by themselves influenced subjective expected utility for smoking, smoking intention, friends' approval of smoking, friends' encouragement of not smoking, and beginning smoking.

Findings:

1. Radio and television messages reached 81 percent of the target audience an average of 4.5 times during each of the three 4-week intervention periods.
2. The media campaign had a modest effect on the expected consequences of smoking and friends' approval of smoking.
3. The radio-only campaign was as effective as television.
4. The peer involvement component was not effective.
5. The campaigns did not reduce the number of new smokers.

A study by Flynn et al. (1992) had a quasi-experimental design, with a survey follow-up. The purpose of the study was to determine whether a mass media campaign plus a school-based cigarette use prevention intervention was more effective in reducing smoking than school-based interventions alone. Another study by Flynn et al. (1994) was a 2-year follow-up.

Findings: The intervention group showed a consistent trend toward less smoking, with significant differences in the final 2 years.

1. The intervention group reported significantly more negative attitudes toward tobacco use than did the control group in years two through five.
2. The effects of the intervention persisted 2 years after its completion.

In a formative evaluation, McKenna and Williams (1993) developed and tested a mass media campaign message designed to increase awareness among adolescents about the marketing tactics of the tobacco industry and to strengthen antitobacco attitudes among adolescents. This study utilized focus group discussions to plan campaigns and to test finished counteradvertising approaches and campaign materials. Although research on youth was used to prepare the messages, adolescents were not consulted during the preparation of these television spots.

Findings: Few (26 percent) adolescents understood that the proposed television spot illustrated tobacco industry marketing tactics.

1. Thirty-eight percent of adolescents thought the television spot promoted smoking, few (10 percent) understood the references to the tobacco industry, and older adolescents (ages 13--15) more often than younger adolescents (ages 10-12) were able to identify the message correctly. Because the adolescents were unable to understand the campaign messages, the message was not aired.

Popham et al. (1994) evaluated the effectiveness of a 1990--1991 Tobacco Education Media Campaign conducted by the California Department of Health Services. The 15-month media campaign produced more than 50 television spots, 50 radio spots, 20 outdoor advertisements, and 40 newspaper advertisements. These were placed through numerous television stations, 69 radio stations, 775 outdoor venues, and 130 newspapers. The media campaign was targeted at school-age youth and adult smokers. The campaign was designed so that youths' exposure would be approximately one-third greater than that of adults. The themes employed included the adverse health and interpersonal consequences of tobacco use, society's increasing disapproval of smoking, and the profit motivation of the tobacco industry. In this time series, nonexperimental evaluation, precampaign baseline measurements were compared with quarterly postcampaign measurements regarding awareness of the campaign, tobacco use, smokers' intention to quit, nonsmokers' intention to start smoking, and attitudes toward smoking. The following results are limited to data derived from evaluation of 29,264 students in grades 4 through 12.

Findings: Among students exposed to the media campaign, there was an increase in awareness of the media campaign, a decrease in the percentage of students who were smokers, an increase in the proportion of smokers with an intention to quit, and an increase in health-enhancing attitudes.

1. At the final measurement, students who had been exposed to the media campaign demonstrated stronger health-enhancing attitudes than did their unexposed counterparts.

In a 5-year study, Murray et al. (1994) used a time series cross-sectional survey to examine the effects of a prevention approach that included mass media messages on adolescent beliefs and behaviors. They assessed the amount of student exposure to mass-media messages on tobacco use prevention and determined whether beliefs, attitudes, and behaviors related to tobacco use changed as a result of this exposure.

Findings: Students exposed to mass media campaigns reported dramatically increased exposure to antismoking messages in the mass media.

1. This exposure had little effect on smoking-related beliefs or behaviors.

### Lessons Learned From Evidence Reviewed

- Counteradvertising, in the form of multicomponent media-based prevention efforts, can increase young people's awareness of media campaigns, decrease their smoking, and decrease their intention to start. Such efforts have also demonstrated an ability to increase negative attitudes toward smoking, increase understanding of the consequences of smoking, and decrease rates of peers' approval of smoking.
- Multicomponent prevention efforts that include media campaigns are more effective than single-component media campaign prevention programs. Media campaigns have been shown to support and promote other components and vice versa. Effective media campaigns involve linkages with other intervention activities.
- To be effective, media messages should be age appropriate and designed with the target audience's developmental stage in mind. In particular, messages should not be too subtle or too sophisticated.

Level of Evidence

The research evidence reviewed indicates that it is possible to implement counteradvertising interventions:

- There is strong evidence that counteradvertising is effective in changing the attitudes of adolescents about tobacco use.
- There is medium evidence that counteradvertising is effective in reducing adolescent tobacco use.

### Suggestions for Future Research

- Counteradvertising as an approach to preventing adolescents' tobacco use is in the early stages of development. Additional research should be conducted with regard to motivational mechanisms. In other words, what are the elements of a media message that motivate people? What components are the most powerful? What is the appropriate execution of messages?

## Prevention Approach 3: Retailer-Directed Interventions

### Intended Measurable Outcome

To reduce access to tobacco products by minors

### Clusters

Within the prevention approach of tobacco retailer-directed interventions, research and practice can be divided into three subgroups, each with its own emphasis. Consequently, tobacco retailer-directed interventions are presented here in three clusters: merchant and community education about adolescent tobacco use and the laws prohibiting tobacco sales to minors, the enactment of laws prohibiting tobacco sales to minors, and enforcement of laws prohibiting tobacco sales to minors plus merchant and community education about minors' tobacco use and the laws prohibiting tobacco sales to adolescents.

Note: In many of the studies in this section, investigators examined local ordinances prohibiting tobacco sales to minors. These studies predated the Synar regulation, which mandates that all States have laws prohibiting tobacco sales to persons 18 years and younger or risk losing substance abuse prevention and treatment block grant funding. The Synar Regulation was made final in February 1996 and is still in the implementation process.

#### Cluster 1: Merchant and Community Education About Adolescent Tobacco Use and the Laws Prohibiting Tobacco Sales to Minors

##### Conceptual Framework

Research demonstrates that adolescents obtain tobacco products through direct purchase from retailers, such as convenience and grocery stores, service stations, and pharmacies as well as through friends and family members, and shoplifting. Therefore, educating merchants, clerks, and the community about youth tobacco use and the laws prohibiting tobacco sales to minors should reduce tobacco sales to minors.

##### Objectives of Studies Reviewed

- To determine whether merchant education combined with grassroots community education reduces the sale of tobacco products to minors
- To determine whether positive reinforcement to clerks and merchants for not selling tobacco to minors and asking for proof of age reduces tobacco sales to minors

##### Activities of Studies Reviewed

- Educating clerks and merchants about the youth tobacco use problem, existing laws prohibiting tobacco sales to minors, and their responsibility for complying with these laws
- Providing information and education to the general public, community groups, and mass media about existing laws prohibiting tobacco sales to minors and about their use of tobacco
- Enlisting community support for activities related to education and interventions regarding tobacco use by youth
- Developing and publicizing the results of surveys of purchase attempts by adolescents
- Providing retail stores with warning signs regarding the laws prohibiting tobacco sales to minors

##### Basis of Evaluation of Evidence

The analysis of the effectiveness of Cluster 1 under Prevention Approach 3, Merchant and Community Education About Adolescent Tobacco Use and the Laws Prohibiting Tobacco Sales to Minors, is based on five research studies (Altman et al. 1989, 1991; Biglan et al. 1994a; Keay et al. 1993; Skretny et al. 1990; Wildey et al. 1995) and one prevention practice case (Tobacco-Free Youth Project).

A study by Altman et al. (1989) had a nonexperimental design with baseline, intervention, and posttest stages. It was designed to determine whether a voluntary education program for merchants, combined with a media campaign and a grassroots community organization, would be effective in reducing the sale of cigarettes to minors in a wide range of stores and communities. Six months after baseline evaluation, an intervention was implemented that involved community and merchant education, as well as contact with chief executive officers of outlet chains and franchises. The investigators later completed a 1-year follow-up study (Altman et al. 1991).

Findings:

1. After the intervention, cigarette sales to minors decreased significantly, from 74 percent at baseline to 39 percent at 6 months and 59 percent at 1 year.
2. At 6 months, vending machine sales to minors remained at 100 percent.
3. Postings of warning signs increased from 3 percent at baseline to 23 percent at 6 months and 25 percent at 1 year.
4. Stores receiving educational kits began posting warning signs more often.
5. The rate at which adolescents were asked for proof of age increased from
6. 24 percent at baseline to 48 percent at 6 months and 34 percent at 1-year follow-up.

A study by Biglan et al. (1994a) was a time-series design involving several communities. This study was conducted to determine whether a community intervention designed to mobilize social and tangible reinforcement for merchants who refused to sell tobacco to minors would reduce tobacco use among adolescents. The intervention consisted of mobilization of community support, merchant education, consequences to merchants for selling tobacco to minors, publicity about merchants' refusal to sell, and feedback to merchants about the extent of their sales to adolescents.

Findings:

1. The proportion of stores willing to sell tobacco to minors after the intervention decreased from baseline as follows:
  - From 57 to 27 percent in Florence
  - From 62 to 17 percent in Reedsport
  - From 65 to 37 percent in the greater Sherwood area
  - From 63 to 22 percent in Hood River

In a quasi-experimental study, Keay et al. (1993) evaluated whether a combination of retail merchant education, mass media efforts, and community education would affect cigarette sales to minors. The study was also designed to evaluate, at 1 month after the intervention, whether these efforts would affect merchant behavior, such as asking apparent minors their age, requesting proof of age, asking whether cigarettes were for minors' own use, discouraging cigarette use, or encouraging cigarette use.

Findings:

1. In the outlets studied, sales to minors decreased from 70 percent to 32 percent.
2. In control outlets, sales to minors decreased from 65 to 59 percent.
3. Study outlets demonstrated significant improvement regarding asking for proof of age and discouraging cigarette use.

In an experimental study, Wildey et al. (1995) examined the effects of a retailer-directed education intervention to reduce tobacco sales to minors in six low-income, ethnically diverse communities. The study involved a control group and an intervention group of retailers that received three quarterly educational visits from project staff over a 1-year period. During these visits, agency staff delivered educational materials for managers, salesclerks, and customers. At the same time, the program employed community education and media strategies to encourage retailer compliance and to promote community awareness, including release of baseline adolescent purchase attempt results to media. Purchase attempts were also made immediately following the intervention and 6 months postintervention.

Findings:

1. At baseline, purchase attempts were successful in 68 percent of the retail stores.
2. Posttest purchase attempts were successful in 32 percent of the intervention stores and 59 percent of the control outlets.
3. At 6 months following the conclusion of the intervention, compliance rates for the intervention group were found to be stable, with the control group showing a slight but insignificant decline.

The purpose of a quasi-experimental study by Skretny et al. (1990) was to evaluate the effect of a merchant education and awareness intervention on compliance with the State law that prohibits tobacco sales to minors and requires posting of warning signs. The intervention involved a letter to store managers requesting them to comply with the State law regarding sales and signs and to post warning signs about tobacco sales to minors. The letter was accompanied by a tip sheet for educating store employees about the illegality of tobacco sales to minors. Adolescent purchase attempts were made 2 weeks after the intervention.

Findings: Two weeks after the merchant education intervention:

1. Tobacco sales to minors did not significantly differ between stores receiving the mailing and others.
2. There was a statistically significant difference in the posting of warning signs between study stores (40 percent) and control stores (0 percent).

The Tobacco-Free Youth Project of theCOMMIT to a Healthier Raleigh Project was designed to increase public awareness concerning cigarette sales to minors and merchants' voluntary compliance with the State law prohibiting tobacco sales to minors. The project involved cigarette purchase attempts by adolescents, media coverage of the results of the purchase attempts, and a community-wide education campaign designed to inform the public and merchants about the law and to facilitate merchant compliance with the law. After the campaign, the project evaluated the effect through adolescents' purchase attempts made on July 13, 1991, with a press conference publicizing results on July 31. In September, the merchant education program began. Purchase attempts were again made in April (vending machines only) and June (over-the-counter and vending machines).

Findings:

1. Purchase attempt rates dropped from a baseline rate of 64 percent to 32 percent after the intervention. Based on evidence derived from the baseline evaluation, the Raleigh City Council voted to ban cigarette vending machines from establishments without Alcoholic Beverage Control permits.

#### Cluster 2: Enacting Laws Prohibiting Tobacco Sales to Minors

##### Conceptual Framework

Research demonstrates that adolescents obtain tobacco products through direct purchase from retailers, such as convenience and grocery stores, service stations, and pharmacies as well as through friends and family members, and shoplifting. Therefore, enacting laws prohibiting tobacco sales to minors should reduce tobacco sales to them.

##### Objectives of Studies Reviewed

- To determine whether enactment of laws restricting tobacco sales to minors or an increase in penalties to merchants for violating these laws would result in changed attitudes and behaviors on the part of merchants regarding sales to adolescents
- To determine whether a comprehensive ordinance restricting tobacco sales to minors would have an effect on sales to minors
- To determine whether an ordinance that mandates locking devices on cigarette machines would decrease sales from cigarette machines to minors

##### Activities of Studies Reviewed

- Enacting local ordinances restricting the sale of tobacco to minors
- Placing cigarette vending machines in locations inaccessible to minors
- Requiring locking devices on cigarette vending machines that require merchant or clerk assistance to permit operation
- Requiring merchant licenses for vending machines or for over-the-counter sales of tobacco products
- Requiring merchants to ask customers who appear to be underage for proof of age during tobacco purchase attempts
- Requiring warning signs in stores that remind merchants, clerks, and customers about laws restricting tobacco sales to minors
- Enacting penalties, such as license suspension or revocation or civil penalties, for violating laws restricting tobacco sales to minors

##### Basis of Evaluation of Evidence

The analysis of the effectiveness of Cluster 2 under Prevention Approach 3, Tobacco Retailer-Directed Interventions, Enacting Laws Prohibiting Tobacco Sales to Minors, is based on four research studies (Forster et al. 1992a, 1992b; Hinds 1992; Jason et al. 1991).

Level of Evidence

The research and practice evidence reviewed indicates that interventions can be designed to provide merchant and community education about adolescent tobacco use and the laws prohibiting tobacco sales to minors:

There is medium evidence that combined merchant and community education results in a short-term decrease in over-the-counter tobacco sales to minors.

A study by Forster et al. (1992a) had a nonexperimental design with baseline, intervention, and posttest phases. The purpose of the study was to determine whether locking devices on cigarette vending machines would decrease the ability of adolescents to use them. Cigarette purchases were attempted at three points: shortly before the enactment of a law requiring locking devices, 3 months after baseline, and 1 year after baseline.

Findings:

1. Three months after the enactment of the law, 34 percent of the businesses had machines without locking devices.
2. One year after the enactment of the law, 30 percent of the businesses had vending machines without locking devices.
3. The percentage of purchases by adolescents decreased from 86 percent before the law to 30 percent at 3 months and 48 percent 1 year after implementation.
4. One year after enactment, businesses that had installed locking devices were selling fewer cigarettes to minors than were businesses with unlocked machines.
5. One year after enactment, businesses that had switched to over-the-counter were selling the fewest cigarettes to minors.

Another study by Forster et al. (1992b) had a cross-sectional multiple evaluation design. It was conducted to establish baseline data on adolescents' ability to purchase cigarettes over the counter at convenience and grocery stores, gas stations, pharmacies, and bars as well as from cigarette vending machines in these establishments. In addition, this study was designed to assess the short-term effect of a Minnesota law that increased the penalty for cigarette sales to minors from a petty misdemeanor to a gross misdemeanor. The baseline purchase attempts were made about 1 month before the enactment of the law, with a policy change evaluation about 1 month after enactment.

Findings:

1. At baseline, purchase attempts were successful at 53 percent of over-the-counter sites and were 79 percent successful at vending machines.
2. Purchase attempts were most successful at gas stations, grocery stores, and convenience stores.
3. Vending machine purchase attempts were successful at 99 percent of gas stations and 88 percent of restaurants.
4. After enactment of the law, over-the-counter purchase attempts by adolescents were 38 percent successful.
5. The enactment of the law did not result in measurable changes in vending machine purchases.

Hinds (1992) conducted a nonexperimental study with baseline, intervention, and posttest measures to determine whether a city ordinance prohibiting tobacco sales to minors had resulted in decreased access to and use of tobacco by 10th grade students. In particular, the survey assessed whether the city ordinance prohibiting tobacco sales to minors had affected regular tobacco use, the type of tobacco used, the source for obtaining tobacco, and the rate of being asked for proof of age by merchants and clerks. The baseline survey was conducted 3 months before and the post-ordinance evaluation about 10 months after enactment of the law.

Findings:

1. There was an overall reduction in subjects' tobacco use, but this finding was statistically significant only for girls.
2. There was a tendency toward less use of stores and more use of vending machines, friends, and theft to obtain tobacco, but this was statistically significant only for use of friends.
3. For tobacco-using subjects, there was an increase in being asked for proof of age when attempting to purchase tobacco.

A study by Jason et al. (1991) had a nonexperimental design with baseline, intervention, and posttest measurements. The purpose of the study was to determine the effect on tobacco sales to adolescents and on the incidence of their tobacco use after multiple interventions of enactment of a local ordinance, with media attention and the threat of vendor license revocation and police visits to each store; quarterly compliance checks by the police; letters from the police to cigarette vendors; and letters from the police to students' parents. Assessments were conducted in August and November 1988 and February 1989. The law was implemented in May 1989. Post-ordinance evaluations were conducted in June, August, and November 1989 and in January, April, July, and December 1990.

Findings: Following the enactment of the ordinance:

1. Sales of cigarettes to minors dramatically declined.
2. The number of stores complying with the ordinance increased dramatically.
3. Experimental and regular use of cigarettes by minors decreased.

#### Cluster 3: Enforcing Laws Prohibiting Tobacco Sales to Minors Plus Merchant and Community Education About Adolescent Tobacco Use and the Laws Prohibiting Tobacco Sales to Adolescents

##### Conceptual Framework

Research demonstrates that adolescents obtain tobacco products through direct purchase from retailers, such as convenience and grocery stores, service stations, and pharmacies as well as through friends and family members, and shoplifting. Therefore, enforcing laws prohibiting tobacco sales to minors, in addition to educating merchants, clerks, and the community about these laws and about adolescents' tobacco use, should reduce tobacco sales to minors.

##### Objectives of Studies Reviewed

- To determine whether the combination of enforcement of laws prohibiting tobacco sales to merchants plus merchant and community education regarding adolescents' tobacco use and the laws prohibiting tobacco sales to them will decrease long-term sales of tobacco to minors
- To determine whether the addition of enforcement of existing ordinances to merchant and community education will result in a greater decrease in tobacco sales to minors

Level of Evidence

The research evidence reviewed indicates that laws can be written and established that increase the penalties for selling tobacco to minors:

- There is medium evidence that laws increasing penalties for tobacco sales to minors have a short-term effect in reducing over-the-counter tobacco sales to minors.
- There is substantial evidence of the ineffectiveness of enacting ordinances requiring locking devices on cigarette machines to reduce access by minors to cigarettes. Ordinances requiring locking devices are ineffective because merchants frequently leave the machines unlocked. The devices are perceived as an additional burden and are a low priority for law enforcement.

##### Activities of Studies Reviewed

- Seeking and securing community partnership, support, and sponsorship of prevention activities from local businesses, community organizations, local and mass media, local law enforcement, the judicial system, district attorneys, and other government agencies
- Establishing the rate of tobacco sales to minors through the use of purchase attempts by adolescents
- Visiting retail merchants to educate them about the laws prohibiting tobacco sales to minors and the consequences of noncompliance
- Combining youth with law enforcement personnel to deliver merchant education about adolescent tobacco use and the laws prohibiting tobacco sales to adolescents
- Providing merchants with educational materials about adolescents' tobacco use, fact sheets, tips for refusing sales to minors, copies of the State and local laws prohibiting tobacco sales to minors, and store warning signs about these laws
- Publicizing adolescent purchase attempts conducted by law enforcement officials that result in penalties to merchants
- Providing reinforcement to merchants for not selling tobacco to adolescents, including financial rewards, consumer product incentives, public recognition in local newspapers, and positive publicity through mass media
- Media activities such as press conferences, advertisement of activities, and coverage of activities

##### Basis of Evaluation of Evidence

The analysis of Cluster 3 under Prevention Approach 3, Tobacco Retailer-Directed Interventions, Enforcement of Laws Prohibiting Tobacco Sales to Minors Plus Merchant and Community Education About Adolescent Tobacco Use and the Laws Prohibiting Tobacco Sales to Adolescents, is based on two research studies (Feighery et al. 1991; Jason et al. 1991) and five prevention practice cases (Project SCAN; The Dover Youth Access to Tobacco Reduction Program; the Pajaro Valley Prevention and Student Assistance program; the Stop Tobacco Access for Minors Project (STAMP); and the Stop Teenage Addiction to Tobacco project).

A study by Feighery et al. (1991) involved a nonexperimental design with a baseline and two posttest assessments. The goal of the study was to determine whether a comprehensive educational intervention directed at merchants, law enforcement agencies, and the community, in combination with well-publicized enforcement operations by the police department, would reduce tobacco sales to minors. The pretest measurement of the sales rate was conducted between June and August 1988, the comprehensive education intervention began in September 1988, and the first posttest measurement was conducted in December 1988. A law enforcement intervention began in November 1989, and the final posttest assessment was conducted in May 1990.

Findings:

1. Comprehensive community education, in combination with police enforcement, significantly reduced over-the-counter tobacco sales to minors.
2. These efforts did not decrease sales to minors from vending machines.
3. The comprehensive community education effort alone had a limited effect on the reduction of tobacco sales to adolescents.
4. Judges often suspended the sentences of merchants.

A report by Jason et al. (1991) describes two studies with nonexperimental designs having baseline and posttest evaluations. The purpose of the studies was to determine whether a local ordinance prohibiting cigarette sales to minors had reduced the rate of cigarette sales to minors. The study also evaluated whether a local ordinance prohibiting cigarette sales to minors reduced the incidence of smoking among minors. The intervention included letters to merchants from a police officer; enactment of a local ordinance, with appropriate media coverage, vendor licensing, and visits by police to each store; quarterly purchase attempts by adolescents with police enforcement for violations; and letters from the police to students' parents. Assessments were made in August and November 1988 and February 1989. The law was implemented in May 1989. Post-implementation evaluations were conducted in June, August, and November 1989 and January, April, July, and December 1990.

Findings:

1. Cigarette sales to minors declined dramatically after enactment of the ordinance (baseline rates of 70, 60, and 79 percent; postintervention rates of 35, 36, 0, 4, and 3 percent).
2. The experimental and regular use of cigarettes by minors decreased after enactment of the ordinance.

Project SCAN (Stop Children's Addiction to Nicotine) was designed to increase public awareness of the problem of adolescents' tobacco use, increase merchant education about the tobacco access law to promote voluntary compliance, and encourage local police to enforce the tobacco access law. Two case examples describe how this project was implemented in two New York communities.

Findings:

1. Many individuals, businesses, organizations, and government agencies provided support to and sponsorship of the activities.
2. The police delivered educational information to merchants and participated in purchase attempts by adolescents.
3. Most retailers received an information packet and displayed warning signs.
4. Prevention publicity prompted police enforcement and legislative initiatives.
5. It was difficult to convince police officials to enforce tobacco access laws.
6. Judges dismissed merchant sentences imposed for violating the law.

The Dover Youth Access to Tobacco Reduction Program was developed to prevent or reduce adolescent tobacco use. Attempts by adolescents to purchase tobacco were made through the program, and merchants were invited to attend a tobacco education seminar on adolescent tobacco use and laws restricting tobacco sales to adolescents. Officials also issued warnings to merchants who violated the laws during purchase attempts by adolescents. These merchants were revisited 1 year later and were issued a court summons if they continued to sell tobacco to adolescents.

Findings:

1. The successful adolescent tobacco sales rates were 73 percent before program implementation and 24 percent after the implementation.
2. After implementation of the intervention, 60 percent of attempted purchases from vending machines by minors were successful.
3. After implementation, 16.6 percent of over-the-counter purchase attempts by minors were successful.

The Pajaro Valley Prevention and Student Assistance program was designed to create a comprehensive tobacco control program to address use of tobacco products by youth and the role of adults in supplying tobacco products to minors. Purchase attempts by adolescents were made in December 1990, the results of which enabled the passage of a vending machine ordinance in March 1991. Merchant education visits by trained youth and police were conducted in August 1991. In August 1993, program staff conducted follow-up merchant education visits. The program works in partnership with numerous community elements.

Findings:

1. Before enactment, 62 percent of over-the-counter purchase attempts and 100 percent of vending machine purchase attempts were successful.
2. Using these survey results, the county coalition introduced and passed vending machine ordinances throughout the county.
3. Three years after the program, most merchants were in compliance with the requirement to display warning signs.
4. Youth participation was constructive.
5. It was difficult to obtain youth participation on Saturday mornings.
6. The police did not perceive youth access laws as a priority and were less responsive than had been anticipated.

The Stop Tobacco Access for Minors Project (STAMP) was created to reduce adolescent tobacco sales by making access to tobacco by adolescents more difficult by promoting public awareness of the extent of tobacco use, providing merchant education and incentives not to sell tobacco to minors, advocating and implementing tobacco access laws, and collaborating with law enforcement agencies to enforce them.

Findings:

1. Purchase attempts by adolescents demonstrated an average reduction of 40 percent in over-the-counter adolescent tobacco sales in targeted cities; in some, a 75-percent reduction.
2. STAMP has helped to enact and implement cigarette vending machine ordinances in 11 jurisdictions and more than 25 comprehensive ordinances against over-the-counter sales, vending machine sales, and free samples for adolescents as well as self-service promotional sales and displays.

The Stop Teenage Addiction to Tobacco project was designed to document the extent of youth access to tobacco, educate the community about the problem of youth access to tobacco, and advocate increased enforcement of California's youth access laws. It was also intended to advocate the passage of regulations to further reduce tobacco sales to adolescents in San Jose.

Findings:

1. As a result of publicizing purchase attempts by adolescents, merchant education, and city council lobbying, an ordinance was enacted that banned cigarette vending machines from all businesses except those serving liquor and required the latter to place the machines at least 25 feet from the entrance.
2. After enactment, publicity regarding high rates of attempted purchases from vending machines by minors led to the removal of all known illegal vending machines in San Jose.
3. Youth involvement generated media interest and public support.
4. Youth testimony helped to pass the vending machine ordinance.

Level of Evidence

The research and practice evidence reviewed indicates that it is possible to implement prevention programs that combine merchant and community education with law enforcement components:

There is medium evidence that combined merchant and community education with enforcement of the law will reduce over-the-counter tobacco sales to minors. Because most localities have only recently enhanced their education and enforcement efforts, there is insufficient evidence that this effect will be sustained over a long period of time or that this approach will reduce tobacco use among youth.

### Lessons Learned From Evidence Reviewed

- Merchant education is a valuable component of community-based prevention strategies. Although merchant education as an independent component of prevention may not yield robust results, it appears to enhance the effect of other prevention components. Similarly, merchant education in the context of a multicomponent community-based prevention program helps to increase promotion of community involvement. It can help merchants to understand their role in community prevention efforts and to perceive themselves as community partners. Merchant education helps other community partners to understand the roles and responsibilities of merchants in a community partnership and diminishes the likelihood of viewing cigarette merchants as adversaries.
- A continuum of effect results from increasing the intensity of interventions; that is, the passing of a law prohibiting tobacco sales to minors without any other intervention will have the least effect. The intervention effect is optimized when there are several components, namely: enacting laws prohibiting tobacco sales to minors, enforcing these laws through publicized purchase attempts with police sponsorship or cooperation, educating merchants and the community about adolescents' tobacco use and the laws prohibiting tobacco sales to minors, seeking comprehensive community support of these prevention efforts, and educating judges and cooperating with them to impose consequences on violators of the tobacco access laws.
- Adolescents can take an active role with adults in education and prevention efforts. They can be effective as partners in educating members of the legislature, local judges, and local organizations and agencies. In particular, adolescents can work as partners with law enforcement officials during merchant education efforts.
- A decrease in sales of tobacco to youth within a given community is not necessarily indicative of decreased availability or accessibility, because they may be able to obtain tobacco in nearby communities. Such effects should be taken into consideration when evaluating community-based tobacco control research.

### Suggestions for Future Research

- Merchant and community education components of prevention programs vary in effectiveness. Therefore, it is recommended that researchers explore areas related to education components, such as the ways in which educational sessions are conducted, what types of materials are most effective, and who can provide the education most effectively.
- Research and experience demonstrate that interventions differ in effects as well as durability of effects. Research is needed to examine individual prevention components, especially those commonly used in multicomponent prevention programs.
- There is a need to examine the cost-effectiveness of specific interventions and multicomponent prevention programs.
- Research should be directed at evaluating the extent to which reducing accessibility and sales of tobacco to youth reduces their consumption of tobacco products.

## Prevention Approach 4: Multicomponent School-Linked Community Approaches

### Intended Measurable Outcome

To mobilize community systems through the schools to discourage adolescent tobacco use

### Clusters

Within the prevention approach of multicomponent school-linked community approaches, research and practice can be divided into three subgroups, each with its own focus. Consequently, multicomponent school-linked community approaches are presented in three clusters: parental involvement, student antitobacco activism, and media interventions.

#### Cluster 1: Parental Involvement

##### Conceptual Framework

Research demonstrates that multicomponent programs are more effective than single-component interventions for the prevention of tobacco use by adolescents. Therefore, adding prevention components based on parental involvement to other prevention efforts, such as school-based programs, should reduce adolescents' use of tobacco.

##### Objectives of Studies Reviewed

- To expose parents to antitobacco messages through multiple channels
- To increase parental knowledge of tobacco problems and antitobacco attitudes and beliefs
- To increase parental awareness of, receptivity to, and participation in smoking prevention programs
- To encourage parents to discuss tobacco-related issues and problems with their children
- To help families develop rules regarding tobacco use within the home
- To determine whether adding a parent component would increase the effectiveness of school-based programs
- To enlist parents in the process of informing and influencing educators and school administrators about adolescent tobacco problems
- To design and determine the acceptability of a culturally appropriate tobacco cessation and prevention intervention
- To assist parents in fostering their children's refusal skills and to change the family norm to nonuse of tobacco

##### Activities of Studies Reviewed

- Parent surveys
- Take-home quizzes for parents and students
- Letters to parents
- Smoking cessation services and self-help materials
- Television segments on prevention and cessation
- Pamphlets for parents that contain information about tobacco problems
- Educational materials for parents with tips on how to encourage their kids not to smoke
- Parent training
- Community organizing regarding school policy and curricula
- Community organizing to promote community change regarding adolescents' use of alcohol, tobacco, and illicit drugs
- Media campaigns
- The "Unpuffables Program" intervention

##### Basis of Evaluation of Evidence

The analysis of Cluster 1 under Prevention Approach 4, Multicomponent School-Linked Community Approaches, Parental Involvement, is based on seven research studies (Biglan et al. 1994b; Flay et al. 1987; Pentz et al. 1989a, 1989b; Perry et al. 1990, 1987; Stevens et al. 1993; Werch et al. 1991) and one practice case (the Multicultural Area Health Education Center).

Biglan et al. (1994b) employed a quasi-experimental design in a year-long study of activities to prevent adolescent tobacco use aimed at adolescents and parents. Parents of middle school students were invited to participate in developing and implementing activities at school to influence parents to talk to their children about not using tobacco. Students were sent home with a quiz about tobacco to complete with their parents. The parents received a letter signed by prominent citizens regarding the quiz, along with answers and information. The students were rewarded for completion of the quiz.

Findings: In comparison with parents in control communities:

1. Significantly more parents in intervention communities talked to their children about not using tobacco.
2. More parents in intervention communities stated that they had explicitly told their children that they did not want them to use tobacco. However, the intervention did not significantly affect how adolescents perceived parental communication, nor did it affect their intention to smoke.

A quasi-experimental study by Flay et al. (1987) was designed to evaluate the effectiveness of a school-based smoking prevention intervention for 7th grade students. Investigators examined the effects of schoolwide implementation, coordination with television programming, and encouragement of parental participation on students. This last component included television program segments that provided parents with a booklet of basic information and homework as well as encouragement by teachers to view the segments and to work with their children regarding social factors that influence children to smoke. The study included student assessments at baseline and at 2 months, 1 year, and 2 years after the intervention.

Findings:

1. Parent-child interaction during the prevention program correlated negatively with increases in intervention subjects' current and cumulative lifetime cigarette use at the first posttest assessment, but was not significant at the second and third assessments.
2. At the 1-year follow-up, parental involvement correlated negatively with the degree of adolescents' perception of peer approval of their smoking and with the number of friends they thought would approve of their smoking.
3. At the 2-year follow-up, there was a significant positive correlation between the number of parent-child activities and adolescents' intention to refuse offers of cigarettes from a group of friends and from a best friend.

Pentz et al. (1989a,,1989b) conducted a quasi-experimental study to evaluate the effectiveness of a school- and community-based program intended to counteract social pressure to use cigarettes, alcohol, and/or marijuana. The intervention included a parent organization program for training parents in parent-child communication and prevention practice support skills as well as organizing to change school policies about institutionalizing drug prevention curricula and restricting drug use in and around schools.

Findings:

1. At the time of the 2-year follow-up, on the basis of the school of origin, smoking by students in intervention schools had increased by 9.1, 9.1, and 6.8 percent for monthly, weekly, and daily periods of measurement, respectively. Student smoking rates in control schools had increased by 15.4, 13.8, and 9.8 for monthly, weekly, and daily periods, respectively. Thus, the overall rate of increase in smoking prevalence for control schools was approximately 1.5 times the rate of increase for intervention schools.

A report by Perry et al. (1990) describes two pilot evaluations. One study had a quasi-experimental design, and the other employed a nonexperimental design. These studies were designed to evaluate the effectiveness of the Unpuffables Program, a school-initiated, family-based, 4-week smoking prevention activity targeting preadolescent students and their parents. Program materials consisted of four packets designed as a family game, using a detective motif, with students receiving rewards for completion. The packets were given to the students, who were instructed to take them home and participate in the program activities with their parents. Telephone survey questionnaires were administered shortly after completion of the 4-week activity.

Findings: Positive findings of the two studies were:

1. Increased parental awareness of the intervention program
2. Adolescents bringing the program home to parents
3. Parent-child participation in the prevention activities
4. Adolescents' initiation of conversations with their parents about smoking
5. Adolescents' encouragement of others to quit smoking

An article by Perry et al. (1987) described several investigations, including a survey component of a larger study with a quasi-experimental design. The purpose of this study was to evaluate whether a smoking prevention and cessation intervention targeted at high school students would have an effect on the beliefs and behaviors of the students' parents. The school-based curriculum intervention was a component of the Keep It Clean II program, a community intervention trial aimed at changing cardiovascular risk behaviors. A telephone survey of parents was conducted during the third year of the intervention.

Findings:

1. More parents in the intervention group (49 percent) than in the control group (35 percent) reported having discussions with their teenagers about smoking in the prior week.
2. More parents in the intervention group (72 percent) than in the control group (42 percent) were aware of the smoking prevention programs in the schools.
3. The intervention (which had no formal parental component) had a minor impact on parental attitude but heightened parental awareness of the program and its content.

A study by Stevens et al. (1993) had a quasi-experimental design and was intended to determine whether a comprehensive school-based substance abuse prevention curriculum, alone or in combination with a parenting course and a community task force, would reduce or prevent smokeless tobacco use by rural preadolescent and young adolescent 4th through 6th grade students. The parent communication course consisted of 10 sessions designed to help parents develop the personal and social skills needed to communicate with their children, especially about risky or unacceptable behavior. Student baseline questionnaires were administered in the spring of 1987, and the intervention began in the autumn of 1987. Posttest surveys were conducted in 1988, 1989, and 1990.

Findings:

1. After 3 years, there were no significant differences in rates of initiation of smokeless tobacco use among the control group, the curriculum intervention group, and the community intervention group of students.
2. More than 10 percent of boys who had been abstainers or initiators at baseline reported regular use of smokeless tobacco at the 3-year follow-up, with no significant difference between the two intervention groups.
3. The comprehensive curriculum, alone or in combination with the parent course and the community task force, did not significantly affect initial or regular use of smokeless tobacco.

Using an experimental design, Werch et al. (1991) conducted a study to determine whether a home-based social skills training program for adolescents and their parents would have an effect on adolescents' beliefs, knowledge, and intention to use drugs; on parents' beliefs and knowledge about drugs; and on the extent of parent-child communication about avoiding and resisting drugs. Fourth, fifth, and sixth grade students received four weekly take-home prevention training lessons designed to be completed with a parent. Survey questionnaires were administered to all students and parents 2 weeks before and 2 weeks after the intervention.

Findings:

1. Students in the intervention group perceived less use of alcohol, tobacco, and marijuana by peers than did students in the control group.
2. Students in the intervention group reported less susceptibility to peer pressure to experiment with cigarettes than did students in the control group.
3. Mothers in the intervention group reported more recent and more frequent communication with their children about how to refuse or avoid drugs than did mothers in the control group.
4. Mothers and fathers in the intervention group reported having more discussions about ways to resist peer pressure to use drugs than did mothers and fathers in the control group.
5. Fathers in the intervention group reported having more motivation to help their children avoid drug use than did fathers in the control group.

The Multicultural Area Health Education Center (MAHEC) project was designed to provide tobacco education and use cessation in the Latino community of East Los Angeles and the San Gabriel Valley in California. The program includes parental education about adolescents' tobacco use. The program is targeted to parents who are not reached by school-based, student-directed smoking education programs and involves classes conducted at local schools, churches, recreation centers, and health clinics.

Specific activities:

1. A tobacco cessation and prevention program with culturally sensitive staff and intervention materials designed for a Latino population
2. An adult smoking education program targeting parents who are not reached by school-based, student-directed smoking education programs to provide information about preventing adolescent use of tobacco
3. Education and prevention component targets parenting groups at schools, clinics, and church groups in the area

Level of Evidence

The research and practice evidence reviewed indicates that it is possible to implement multicomponent prevention programs that combine parental involvement components with other prevention efforts, such as school-based programs:

- There is medium evidence that multicomponent school-linked programs with a parental component promote improved parental knowledge about adolescent tobacco use, the development of negative attitudes by parents toward tobacco use, and the mobilization of parents to speak with their children regarding not using tobacco.
- There is medium evidence that these programs change students' perceptions regarding tobacco use.

#### Cluster 2: Student Antitobacco Activism

##### Conceptual Framework

Research demonstrates that multicomponent programs are more effective than single-component interventions for the prevention of tobacco use among adolescents. Therefore, adding prevention components based on student participation to other prevention efforts, such as school-based prevention programs, should reduce adolescent tobacco use. Student antitobacco activism is defined as participation in planned antitobacco student activities that are designed to raise awareness, educate, or prompt social change.

##### Objectives of Studies Reviewed

- To increase students' knowledge about problems associated with tobacco use
- To promote antitobacco education and to change attitudes of peers
- To teach students positive ways to encourage parents and others to quit smoking
- To create an antitobacco environment
- To teach youth how they can be influenced by tobacco industry advertising campaigns
- To determine predictors of youth participation in antitobacco programs and of tobacco use
- To prompt students to play a prominent role in developing and delivering interesting communications and activities designed for adolescents

##### Activities of Studies Reviewed

- Writing letters to:
  - Members of a favorite baseball team, asking them not to use or endorse tobacco products - A restaurant manager or owner, advocating smoke-free restaurants - Film producers and magazine editors, protesting tobacco advertising
- Holding a poster contest
- Creating antitobacco art projects
- Making floats with an antitobacco theme and participating in community parades and festivals
- Writing and singing antitobacco songs
- Revising school policy regarding tobacco use
- Planning and attending a culturally specific youth health day
- Designing and painting an antitobacco mural at a junior high school
- Participating in the production of antitobacco animated videos, debates regarding tobacco issues, and the development of a smoking education curriculum

##### Basis of Evaluation of Evidence

The analysis of Cluster 2 under Prevention Approach 4, Multicomponent School-Linked Community Approaches, Student Antitobacco Activism, is based on three research studies (Biglan et al. 1994b; Edwards et al. 1992; Elder et al. 1993) and one practice case (Health Is Wealth).

A year-long study by Biglan et al. (1994b) was conducted to evaluate written media campaigns targeting adolescents and parents with messages intended to prevent adolescent tobacco use, using a quasi-experimental design. Adolescents were invited to participate in antitobacco art projects and contests, develop antitobacco posters, write and sing antitobacco songs, participate in antitobacco community events, help revise school tobacco policies, and advocate for smoke-free restaurants.

Findings:

1. Parents and adolescents in the intervention community reported significantly more exposure to antitobacco messages than did parents and adolescents in comparison communities.
2. More intervention parents than control parents reported that not smoking was the most important thing a person could do to remain healthy.
3. Adolescents exposed to the messages had a significantly lower rate of agreement with positive smoking messages than did control students.
4. Adolescents exposed to the antitobacco messages had a significantly higher rate of agreement that tobacco use is a serious societal problem than did control students.

In a cross-sectional evaluation, Edwards et al. (1992) studied 7th grade students who voluntarily participated in an antitobacco activism contest that was a component of a larger research study, Project SHOUT (Students Helping Others Understand Tobacco). The activism components included writing letters to baseball team players and restaurant owners and postcards to magazine editors and a poster contest.

Findings:

1. Student participation in activism correlated positively with high socioeconomic status and living in a suburban or rural location.
2. The highest rate of ever having used tobacco was for white boys with poor grades and friends and parents who used tobacco.
3. This activism program targets low-risk students who may be experimenting but are not smoking regularly.

Elder et al. (1993) conducted an experimental study to evaluate whether a school-based psychosocial tobacco use prevention intervention with booster interventions would reduce tobacco use among 7th and 8th grade students. The curriculum included student participation in antitobacco community action projects, such as writing letters to tobacco companies, magazine editors, and film producers. This 3-year program included four assessments - baseline measurement at the beginning of the 7th grade and posttest evaluations on completion of grades 7 and 8.

Findings:

1. As measured at the end of the 3-year study period, the prevalence of tobacco use in the previous month was 23 percent for the control group and 14 percent for the intervention group.
2. The prevalence of smoking in the previous month was 20 percent for the control group and 13 percent for the intervention group.
3. The prevalence of smokeless tobacco use in the previous month was 5 percent for the control group and 3 percent for the intervention group.

Level of Evidence

The research and practice evidence reviewed indicates that it is possible to implement prevention programs that involve student activism:

- There is medium evidence that students can be mobilized to participate in antitobacco activism within schools and the community.
- There is medium evidence that prevention efforts that include antitobacco activism are effective in improving adolescents' knowledge about tobacco and promoting negative attitudes regarding tobacco use.
- There is suggestive but insufficient evidence that tobacco prevention efforts that include youth participation in antitobacco activism are effective in preventing adolescents' tobacco use, because few studies have assessed this outcome.

The Health Is Wealth prevention project of Asian Health Services in Oakland, California, was designed to provide comprehensive tobacco education, use prevention, and use cessation services in the diverse Asian and Pacific Islander communities in Alameda County, California.

Specific activities:

1. Four hundred Asian and Pacific Islander youth participated in various community activities.
2. Youth participated in the development of a smoking education curriculum.
3. Youth planned for and attended an Asian Youth Health Day, and four youth worked with a muralist to design and paint an antitobacco mural at a high school.

#### Cluster 3: Media Interventions

##### Conceptual Framework

Research demonstrates that multicomponent programs are more effective than single-component interventions for the prevention of tobacco use among adolescents. Therefore, adding media-based prevention components to other prevention efforts, such as school-based prevention programs, should reduce tobacco use by adolescents.

##### Objectives of Studies Reviewed

- To disseminate information about the hazards of tobacco use and the use of marketing techniques by the tobacco industry
- To counteract the influence of tobacco industry media campaigns
- To provide public recognition of antitobacco program implementors and participating students
- To assess the effects of a modular approach with written media campaigns directed toward adolescents and their parents
- To increase negative parental attitudes regarding tobacco use by adolescents
- To provide adolescents with knowledge and skills to resist peer, family, and media influence to use tobacco
- To determine the ability of media-based intervention to enhance the effects of a school-based prevention program

##### Activities of Studies Reviewed

- Mass media events and programs, such as press conferences
- Television-based 5-minute smoking prevention segments coordinated with classroom curricula
- Curricula and other written information for students, teachers, and parents
- Mass media antitobacco advertisements and public service announcements
- News clips, commercials, talk shows, and articles

##### Basis of Evaluation of Evidence

The analysis of Cluster 3 under Prevention Approach 4, Multicomponent School-Linked Community Approaches, The Media, is based on four research studies (Biglan et al. 1994b; Flay et al. 1987; Flynn et al. 1992, 1994; Pentz et al. 1989a, 1989b).

A year-long study by Biglan et al. (1994b) utilized a quasi-experimental design. Targeted toward adolescents and parents, it was conducted to evaluate written media campaigns with messages intended to prevent tobacco use by adolescents. Middle and high school students were invited to participate in a written media campaign to influence young people not to use tobacco. Parents of middle school students were invited to participate in developing and executing written media messages to influence parents to talk to their children about not using tobacco.

Findings:

1. Significantly more parents in intervention than in control communities talked to their children about not using tobacco.
2. More parents in intervention than in control communities stated that they had explicitly told their children they did not want them to use tobacco.
3. The intervention had no significant effect on the adolescents' talking with their parents about smoking or on adolescents' intention to smoke.

A study by Flay et al. (1987) had a quasi-experimental design and was developed to determine the effectiveness of a school-based smoking prevention intervention for 7th grade students by examining the effects of its school-wide implementation, its coordination with television programming, and encouragement of parental participation on students' participation and on their tobacco use. A television station provided schools with prevention curricula for teachers and peer leaders. They provided homework booklets for students and parents. The television station aired 5-minute smoking prevention segments each weekday evening during the same week that the classroom curriculum was implemented. The study included student assessments at baseline and at 2 months, 1 year, and 2 years after the intervention.

Findings:

1. Significantly more students in the intervention group than in the control group had watched at least one television prevention segment.
2. Seventy-seven percent of the students who viewed the segments had persuaded others to view them and/or to participate in other program-related activities.
3. A significant association was found between the number of segments viewed by an intervention student and lifetime cigarette use: the more segments viewed, the lower the increase in lifetime cigarette use.

Flynn et al. (1992) conducted a study to determine whether a combination of mass media and school-based cigarette use prevention efforts was more effective in reducing smoking among adolescents than school-based prevention efforts alone. A 1994 study by Flynn et al. was a 2-year follow-up. Both studies used quasi-experimental designs.

Findings:

1. There was a consistent trend toward less smoking in the intervention group, with significant differences in the final 2 years.
2. The impact of the interventions on the targeted mediating variables was similar for each measure.
3. In years 2 through 5, the intervention group reported significantly more negative attitudes toward tobacco use.

Level of Evidence

The research evidence reviewed indicates that it is possible to develop adolescent tobacco use prevention programs utilizing media components in combination with other prevention efforts (e.g., school-based programs):

- There is medium evidence that exposure to media-based antitobacco interventions in concert with school-based tobacco education can change students' knowledge, attitudes, and beliefs about tobacco use and marketing.
- There is medium evidence suggesting that multicomponent prevention programs that include media-based interventions are effective in preventing tobacco use by adolescents.

Pentz et al. (1989a,,1989b) sought to measure the effectiveness of a school- and community-based program intended to counteract social influences to use cigarettes, alcohol, and marijuana. The study had a quasi-experimental design. The intervention comprised 39 mass-media events and programs as well as news clips, commercials, talk shows, press conferences, and articles. Consultants provided assistance in the development of scripts and program content as well as holding a prevention overview meeting with the nine major television station managers in the Kansas City area.

Findings: At the time of the 2-year follow-up, on the basis of the school of origin, student smoking in intervention schools had increased 9.1, 9.1, and 6.8 percent for monthly, weekly, and daily periods, respectively. Student smoking rates in control schools had increased 15.4, 13.8, and 9.8 percent for monthly, weekly, and daily measurement periods, respectively. Thus, the overall rate of increase in smoking prevalence for control schools was approximately 1.5 times the rate of increase among intervention schools.

### Lessons Learned From Evidence Reviewed

- Programs designed to enhance the effectiveness of school-based curricula result in increased family and student attention to antitobacco messages. However, there is limited evidence that these programs reduce tobacco use among youth.
- The effects of a fully implemented school- and community-based intervention (including parental involvement) to reduce tobacco use by adolescents as part of a broader substance abuse prevention strategy may be limited by the community's view of tobacco use as a minor issue in relation to other forms of substance abuse and the likelihood that addressing adolescent tobacco use will not be considered a priority by the community.
- The effectiveness of multicomponent prevention programs may be multiplicative, that is, the net effect of a program may be greater than the sum of the effects of all its components. The ways in which prevention program components interact with each other and their effects on each other are largely unknown. As a result, it may not be feasible to assess the contribution of each component.
- Students who voluntarily participate in school-based antitobacco activism projects may already be at low risk for using tobacco.

### Suggestions for Future Research

- There is a need to evaluate the effectiveness of multicomponent media and school-based programs in communities with sizeable ethnic and cultural populations.
- Further research is needed to determine the value of a modular approach to conducting media campaigns in community interventions.
- Community antitobacco activism may have an important role in promoting antitobacco attitudes and in counteracting messages from the tobacco industry. Further, antitobacco activism may help to support other elements of a multicomponent prevention program. However, the value of antitobacco activism as an approach requires further study.
- Many prevention practitioners support peer activism as an integral component of a comprehensive prevention strategy. Several States have a Teen Institute for substance abuse prevention, and numerous community activities involve youth as antitobacco activists. Additional information is needed about the tobacco use of adolescents who volunteer to participate in antitobacco activism.
- The ability of parents to influence the substance use choices of their children is strongly suggested by practice evidence and, to a lesser degree, by research. However, there are barriers to the successful implementation of these influences, including parental substance use and addiction, tobacco industry messages, and the selection of user-friendly mediums for the intended messages. Additional research should focus on techniques for engaging parents in the antitobacco crusade, including smoking cessation opportunities for parents who smoke.
- Research suggests that in situations involving a required class assignment for which there are contingencies for completion, studies using parental self-reporting indicate that parents talk to their children about not using tobacco. However, under these circumstances, children's self-reports provide less evidence that their parents talk to them about not smoking. In other words, in these situations, parents perceive that they talk to their children about not using tobacco, but their children do not necessarily share that perception. Additional research is required to determine whether school-based interventions with parent-child components are effective, and if so, how best to implement them.

## Prevention Approach 5: Tobacco-Free Environment Policies

### Intended Measurable Outcome

To create environments that do not expose youth to the use and possession of tobacco

### Conceptual Framework

Research demonstrates that tobacco use and exposure to secondhand tobacco smoke are threats to health. Therefore, policies restricting the use of tobacco in environments such as schools should reduce adolescents' exposure to tobacco and places where they can use tobacco and thus reduce the health risks associated with tobacco use and secondhand smoke. The Goals 2000: Pro-Children Act of 1994 (P.L. 103--227) established a nonsmoking policy at sites housing such children's services as health care, day care, education, or library services. The studies evaluated in this section preceded the enactment of this Federal law. Nevertheless, the following studies provide useful information regarding the development and implementation of policies that restrict tobacco use.

### Objectives of Studies Reviewed

- To develop and implement policies restricting or prohibiting tobacco use by adolescents and adults in recreational, school, and workplace settings
- To evaluate the effectiveness of policies restricting tobacco use on rates of adolescent smoking
- To provide information and services that will assist individuals in developing and complying with policies restricting tobacco use

### Activities of Studies Reviewed

- Reviewing existing laws and compliance with laws restricting tobacco use in certain settings
- Reviewing the effects of school antismoking policies on adolescent smoking
- Providing technical assistance and guidance designed to develop and implement tobacco-free policies and environments
- Providing education and information regarding existing laws restricting tobacco use in certain settings

### Basis of Evaluation of Evidence

The analysis of the effectiveness of tobacco-free environment policies is based on two research studies (Nelson et al. 1993; Pentz et al. 1989c) and one practice case (the Colorado Tobacco-Free Schools and Communities Project).

A study by Nelson et al. (1993) was a cross-sectional national survey of more than 2,000 directors of licensed child day care centers and was designed to determine the prevalence of employee smoking restriction policies, the rate of compliance with State and local employee smoking regulations and State clean-indoor-air laws, and the extent of exposure to environmental tobacco smoke in these settings.

Findings:

1. Forty States regulate smoking in child day care centers.
2. More than 99 percent of the centers had an employee smoking policy that complied with applicable State or local laws.
3. Seventy-two percent of the centers had a written employee smoking restriction policy.
4. Fifty-five percent of the centers had an employee policy prohibiting smoking indoors and outdoors.
5. Twenty-six percent of the centers had an employee policy restricting indoor smoking only.

A cross-sectional study by Pentz et al. (1989c) was conducted to evaluate the effects of antismoking school policies on adolescent smoking through separate surveys for students and school staff. The student survey concerned the amount and prevalence of cigarette smoking, related attitudes and behaviors, and demographic characteristics of more than 4,800 students in 23 California schools. Surveys of school clerks and of science and health education teachers and principals concerned staff and student smoking policies.

Findings:

1. Schools with all four policy components (comprehensiveness, prevention, cessation, and punishment) had a lower smoking prevalence and a lower mean amount of smoking per individual than did schools with fewer components.
2. A high emphasis on prevention and a low emphasis on cessation were associated with a lower amount of smoking in the past week and in the past 24 hours.
3. A high emphasis on prevention correlated with a lower weekly smoking prevalence and a decrease in past-year smoking violations.
4. Neither the provision for punishment nor its severity for smoking had an effect on reported smoking rates.

The Colorado Tobacco-Free Schools and Communities Project was established in 1988 to help Colorado school districts establish policies to prohibit the use of any tobacco products in school, on school grounds, and at school-sponsored activities by students, staff, or visitors. These efforts included workshops, organizations, and written information.

Specific activities:

1. A large assortment of materials were developed to help schools develop no-tobacco policies.
2. By 1993, 48 percent of the State's school districts had a comprehensive no-tobacco policy, compared with 5 percent before the project.
3. In 1992, only 9 percent of the school districts had designated smoking areas for teachers and staff, compared with 64 percent in 1988.
4. In 1994, State legislation was passed requiring all public kindergarten through 12, Head Start, and nursery schools to be tobacco free.

Level of Evidence

The research and practice evidence reviewed indicates that it is possible to implement policies restricting tobacco use in schools and child day care centers:

There is medium evidence that it is possible to persuade organizations to develop policies restricting tobacco use, possession, and exposure for adolescents and adults. Because changes in policy regarding smoking are relatively recent, however, there is insufficient evidence to determine the effect of these changes on adolescents' tobacco use.

### Lessons Learned From Evidence Reviewed

- Smoking regulations can be established through a variety of mechanisms, including State and local laws and policies at businesses, schools, and child care centers. A comprehensive policy can decrease prevalence, especially when the emphasis is on prevention and cessation.
- Harsh penalties for the possession of tobacco products by minors, such as suspension from school, may be ineffective interventions for enhancing the enforcement of antismoking regulations or for preventing or decreasing adolescent tobacco use. Programs that do not emphasize punitive penalties, especially those that provide prevention or cessation services such as tobacco education courses, tobacco cessation programs, or diversion alternatives, may be most effective.

### Suggestions for Future Research

- Policy changes are part of many multicomponent tobacco prevention efforts. As a result, it can be difficult to determine what effect nonsmoking policies have on the prevalence of adolescent tobacco use. Therefore, research is recommended to examine the effect of policies regulating tobacco use on the prevalence of adolescent tobacco use.
- Furthermore, researchers should study the effects of the severity of penalties on adolescent smoking, as well as the effects of alternative penalties and approaches such as diversion.
- Researchers should determine the extent of compliance with existing smoking policies in all environments.

## Prevention Approach 6: Restriction of Advertising and Promotion

### Intended Measurable Outcome

To decrease exposure of children to tobacco promotion and pro-tobacco influences

### Conceptual Framework

Research demonstrates that tobacco company sales promotions are reaching adolescents and that may put them at greater risk for smoking. Therefore, the reduction of youth exposure to particular types of marketing or to the quantity of marketing should reduce adolescent smoking.

### Objectives of Studies Reviewed

To eliminate tobacco industry sponsorship of sporting and cultural events and to provide alternative sponsorship

### Activities of Studies Reviewed

Providing media advocacy and the threat of adverse publicity through protesting of events sponsored by the tobacco industry:

- Assisting event promoters with obtaining alternative funding
- Developing policies to ban tobacco industry sponsorship of sporting and cultural events
- Promoting tobacco-free events
- Developing tobacco-free messages for sports education curricula
- Advertising tobacco-free events
- Disseminating tobacco-free messages through promotional materials

### Basis of Evaluation of Evidence

The analysis of the effectiveness of advertising and promotion restriction interventions is based on four prevention practice cases (the Coalition for a Tobacco-Free Monterey County [Monterey Blues Festival], the Ski Tobacco-Free Project, the Tobacco-Free Soccer League Initiative, and the Coalition Against Uptown Cigarettes).

The Coalition for a Tobacco-Free Monterey County announced through a press conference that it would protest the then-named Benson and Hedges Monterey Blues Festival because the festival received tobacco industry funds. The announcement was intended to influence the festival's Board of Directors to seek alternative sponsorship. Completely eliminating tobacco sponsorship from this event took approximately 1 year.

Findings:

1. Adverse publicity through the press conference and the threat of protesting the festival led to negotiations that resulted in the festival producer's agreement that tobacco sponsorship would no longer be accepted if the protest were canceled.
2. The festival now has a written policy prohibiting acceptance of money from the tobacco industry.
3. Alternative funding has been sought.

The Ski Tobacco-Free Project (STFP), an activity of the Kirkwood Ski Education Foundation, was designed to counter tobacco industry promotion of skiing events by linking strong antitobacco messages with athletic excellence and to provide alternative sponsorship for ski events, collaborate with the U.S. Ski Association and the Kirkwood Ski Resort's marketing department in the development of an antitobacco campaign, implement an educational program for youth and their parents, and work with statewide media campaigns in the promotion of the project in newspapers and sports-related magazines. STFP has been funded since 1992. When the funding period ends, Kirkwood will sustain the program activities.

Findings:

1. STFP influenced the Kirkwood Ski Resort to develop a tougher tobacco control policy.
2. The Kirkwood Ski Resort sought out and now receives support from ski equipment manufacturers as an alternative to tobacco industry sponsorship of ski events.
3. All amateur skiers in Northern California have been exposed to tobacco-free messages through the sponsorship of local ski events.
4. The U.S. Ski Association has implemented a policy at the national level that bans tobacco industry sponsorship of any Association events.

Level of Evidence

The practice evidence reviewed indicates that it is possible to implement efforts designed to eliminate tobacco sponsorship of events, to block tobacco product promotion, and to provide nontobacco industry sponsorship of events:

- There is strong evidence that such efforts can establish policies that ban tobacco industry sponsorship of social and cultural events and influence product promotion practices.
- There is medium evidence that policies banning tobacco industry promotion of activities such as music festivals and sporting events will reduce adolescents' exposure to tobacco industry messages.

The Tobacco-Free Soccer League Initiative was designed to help youth soccer leagues enact no-smoking policies, to educate youth soccer players about the harmful effects of tobacco, and to provide cessation referrals to coaches, parents, players, and other adult leaders. The initiative was funded in 1992. (No information was available on the length of the funding period.)

Findings:

1. Three California youth soccer leagues with more than 5,000 players have enacted no-smoking policies.
2. The tobacco-free soccer message has reached more than 4,000 people who attend the leagues' annual soccer shows.
3. The project has received numerous requests from other leagues for technical assistance in establishing no-smoking policies.

The Coalition Against Uptown Cigarettes was a group of approximately 125 individuals representing 40 organizations, led by prominent Philadelphia African Americans, organized to protest the introduction of the Uptown brand of cigarettes. R.J. Reynolds had planned to test market the mentholated cigarette in Philadelphia among African Americans. In a 30-day campaign, the coalition focused on media relations and community mobilization with the goal of getting African American smokers to refuse to participate in the planned 6-month market test. After R.J. Reynolds decided not to promote the new cigarette, the coalition became a permanent entity, the Uptown Coalition for Tobacco Control and Public Health.

Findings:

1. R.J. Reynolds decided not to test market Uptown cigarettes in Philadelphia.
2. R.J. Reynolds decided not to produce Uptown cigarettes at all.
3. The ad hocCoalition Against Uptown Cigarettes was transformed into a permanent organization.

### Lessons Learned From Evidence Reviewed

- Alternative funding is an essential component for interventions that are designed to prohibit tobacco industry sponsorship of an event. In particular, practitioners and community groups can develop lists of potential alternative sponsors for event promoters and help promoters seek alternative sponsorship. For example, local businesses that are not currently involved in sponsoring the event can be approached.
- The establishment of working relationships with local businesses can lead them to view sponsorship of events as part of their civic responsibility and as part of a community partnership process. In addition, current sponsors may be willing to increase their level of sponsorship to cover the loss of tobacco industry sponsorship. They may also recommend other potential sponsors, perhaps some of their business partners.

### Suggestions for Future Research

Although advertising restriction interventions are promising approaches for eliminating sponsorship of events by the tobacco industry, research is needed to answer questions such as the following:

- What conditions and program elements made the interventions successful? Was there a specific combination of elements that made the events successful? Did these interventions result in a decrease in adolescents' tobacco use?
- At tobacco-free events, what specific marketing approaches are successful in linking athletic excellence and tobacco-free sports? What are the possible unintended results of such advertising?
- Who are the key decisionmakers at organizations who should be approached to promote policy changes? Should they be frontline workers, public relations staff, or members of boards of directors?
- What specific content of policies is vital to their implementation?
- What are effective methods of finding alternatives to tobacco funding?
- What are the effects of tobacco-related paraphernalia and tobacco advertising billboards?
- What is the effect of tobacco advertising in magazines that are read by adolescents? How will these effects be influenced by the FDA final rule?

## Recommendations for Practice

This section presents the Expert Panel's recommendations, suggestions, and observations regarding the prevention approaches evaluated in the preceding section. Recommendations are given for each of the six prevention approaches as well as for general activities that apply to more than one prevention approach.

### Types of Recommendations

The recommendations that follow vary considerably in nature and intent. Some are practical suggestions for the optimal implementation of a particular intervention, whereas others suggest techniques and precautions to avoid problems. A few are practical observations as to what to expect during certain prevention activities. Still others interpret research findings or illustrate the practical context of prevention efforts. Some recommendations reflect expert opinions of the panel members, such as the assumptions and hypotheses behind certain prevention activities. Many represent "best practices" among prevention experts.

Some recommendations relate to the design and implementation of prevention interventions, a comprehensive discussion of which is presented in Chapter 4.

### Basis of Recommendations

These recommendations are based on the research and practice evidence reviewed in the Analysis of Evidence section as well as other evidence not described there and the professional experience and opinions of the Expert Panel members. This section is illustrative of information transfer from prevention research and practice experts to prevention decisionmakers who need practical information, such as State and local prevention authorities, prevention practitioners and researchers, and members of community prevention organizations. Many of the recommendations are derived from the experience of Expert Panel members during their involvement in research or practice activities not described in this chapter and have not been evaluated in research studies.

### Recommendations for Prevention Approach 1: Economic Interventions

The Expert Panels' recommendations regarding economic interventions focus on allocation of revenues, policy, and media efforts.

- Laws creating tobacco tax increases can include an allocation of resulting revenues for community health education, tobacco use prevention and cessation programs for all ages, and tobacco-related prevention and disease research.
- Experience suggests that there will be strong lobbying from the tobacco industry to decrease the amount of suggested tobacco taxes. As a result, some prevention groups have lobbied for, and others may lobby for, the highest tax possible.
- Experience also suggests that there will be aggressive advertising by the tobacco industry against tobacco tax increases. An aggressive mass media campaign should therefore be an integral component of prevention efforts, with sustained and intense media interaction, providing the media with such information as the names of community prevention partners and announcements of newsworthy activities. Results of purchase attempts by adolescents locally and regionally can be provided for media coverage. In addition, the media can be given information about tobacco industry efforts, strengthened through the use of scientific data or quotes from authoritative organizations such as the American Cancer Society.

### Recommendations for Prevention Approach 2: Counteradvertising

The Expert Panels' recommendations regarding counteradvertising focus on youth participation, media messages, and sustained efforts:

- Adolescents can help adults understand the beliefs, attitudes, perspectives, and opinions of young people. They can be motivated to participate in efforts to prevent tobacco use by adolescents. Therefore, youth can have a valuable role in the planning and development of counteradvertising programs.
- Providing too much information at one time can weaken a mass media campaign. Media campaigns should have simple and focused messages that can be understood by the target audience.
- Adolescents can play an important role in the formative evaluation of potential prevention approaches. Media approaches, especially counteradvertising, should be evaluated by adolescents prior to implementation, such as through focus groups and surveys. Indeed, one study noted that the goals and aims of one media-based prevention effort were not understood by the youths at whom it was directed.
- When possible, mass media campaigns should include television, radio, billboards, and print media. Radio, however, may be the most cost-effective approach.
- The studies by Glantz (1993) and Popham et al. (1994), of the effect of a 1990--1991 tobacco education media campaign conducted by the California Department of Health Services suggest that a statewide multimedia antismoking campaign has a role in decreasing cigarette use. Proposition 99 included a 25-cent cigarette tax increase and a media campaign involving paid advertising to promote media messages; a full range of communication approaches, including public and community relations; and mass media messages targeting the general public and cultural groups such as African Americans, Hispanics, Vietnamese, Koreans, Japanese, and Chinese. The enactment of Proposition 99 resulted in a tripling of the rate at which cigarette consumption had been falling. Students demonstrated an increase in awareness of the media campaign, a decrease in the percentage who were smokers, an increase in the proportion of smokers intending to quit, and an increase in health-enhancing attitudes. Campaign-exposed students demonstrated stronger health-enhancing attitudes than did their nonexposed counterparts. Since the media campaign was suspended as a result of efforts by the tobacco industry, such studies demonstrate the need to continue to counter tobacco industry influence.
- Because tobacco use norms are changing rapidly and new generations of adolescents will view tobacco use differently, media approaches should constantly be modified and tailored to encourage antitobacco attitudes and nontobacco use as the norm among new generations of youth.

### Recommendations for Prevention Approach 3: Retailer-Directed Interventions

The Expert Panels' recommendations regarding retailer-directed interventions emphasize community readiness for change and improving the effectiveness of prevention efforts:

- It is important to document the magnitude of the problem of youth access to tobacco in one's community. Providing profiles and descriptions of the local community increases awareness of adolescent tobacco use problems. Also, such documentation can stimulate community interest in taking action.
- Communities differ in their readiness for prevention efforts, especially those that involve community organizing. Some communities seem primed for establishing comprehensive prevention efforts, whereas others do not recognize tobacco use by adolescents as a major concern. Thus, analysis of community readiness must precede attempts to engage reluctant communities in prevention efforts.
- Those who assess community readiness should also assess the readiness of organizations that apply as lead agencies for prevention projects. In some communities, lead agencies, such as hospitals, schools, and substance abuse agencies, may be reluctant to engage in controversial activities such as compliance checks, even when their contract mandates them. Community readiness for prevention efforts can be increased by first obtaining the support of community leaders for education efforts. Obtaining local community support helps to set the stage for more aggressive action, if necessary.
- Adolescents' access to tobacco is not limited to direct purchase at stores, but includes purchase, receipt, or theft from adults and peers, theft from stores, and receipt of free samples in cigarette giveaways. Therefore, researchers and practitioners should consider means of access other than stores.
- Research and experience suggest that prevention issues and messages should be appropriate for the community. Local and small media therefore should be primary components of all prevention efforts. These can include local print, radio, and television media, when available, as well as newsletters of agencies and organizations.
- Research and experience also demonstrate that adolescents have nearly unrestricted access to tobacco vending machines, despite laws prohibiting tobacco sales to minors. Similarly, research and experience demonstrate that locking devices on tobacco vending machines are ineffective in practice because compliance with the operating procedure is low. Although the FDA final rule includes restrictions on vending machines, communities can apply for waivers to develop even more restrictive laws.
- Prevention efforts should be part of a sustained process, not discrete and isolated events. In addition, it is important to show that the prevention process is effective. Therefore, interventions such as purchase attempts by adolescents, should be regularly scheduled and their results heavily publicized. Interventions should be continually assessed and improved. The community partnership should be continually strengthened with new members, and community education should be ongoing.
- One aspect of an effective approach for enforcing laws prohibiting tobacco sales to minors is the enactment and enforcement of licensure of retail tobacco outlets. In this way, only stores with tobacco licenses can sell tobacco. Furthermore, violation of the tobacco access laws can result in suspension or revocation of the tobacco license. This creates an incentive for the merchant to comply with the law. Some States use their alcohol licensing law as the model for their tobacco licensing law. However, the wording of the alcohol licensing law should be carefully examined. The law may contain language that hampers enforcement (e.g., "knowingly sell") or ban the use of minors for compliance checks.
- Even where there is a comprehensive prevention program, violators of the tobacco access laws are often not disciplined, fined, or sentenced. Judges report that they are reluctant to impose the legal consequences because they view the crimes as minor and do not want the merchants to have criminal records. This is especially true in small cities. Therefore, because the judicial system is an important link in a comprehensive prevention program, judges should be approached and included as members of community partnerships. This can be particularly important when law enforcement partners are active. The police may become reluctant to pursue further efforts if they see that judges are throwing the cases out of court.
- Prevention programs should include incentives to clerks and merchants for not selling tobacco to adolescents, asking for proof of age, and obeying other aspects of the law. Such incentives might include local media publicity and rewards, such as free dinners or products donated by local restaurants and merchants.

### Recommendations for Prevention Approach 4: Multicomponent School-Linked Community Approaches

The Expert Panels' recommendations regarding multicomponent school-linked community approaches focus on improving the impact of mass media interventions:

- The impact of mass media interventions on adolescents is more likely when the interventions:
  - Are linked with other program channels, such as schools, parent groups, and newsletters - Share common objectives with school programs - Are of sufficient duration - Use multiple channels - Are presented where and when adolescents report their highest use of media - Use a variety of message styles - Appeal to age- and gender-specific motives that have been determined through formative research - Use messages portraying perceived social support with age- and gender-relevant models providing appropriate behavioral skills, alternatives, and reinforcement - Include media-based antitobacco information that can reach students within schools and communities. Programs that use media approaches should be prepared to measure the extent to which the target audience is exposed to the message.
- Visual rather than written intervention materials may be more appropriate and effective for groups with low literacy rates, especially adult Asian and Pacific Islander immigrants, refugees, and certain high-risk youth.

### Recommendations for Prevention Approach 5: Tobacco-Free Environment Policies

The Expert Panels' recommendations regarding tobacco-free environmental policies focus on the target of policies and community support:

- Policies restricting smoking that are selectively applied may be ineffective and may send a mixed message. For instance, a school-based policy that enforces the legal ban on tobacco use by students, but allows the legal use by teachers and staff, sends the message that tobacco use among adults is acceptable. Therefore, a smoking policy should be designed for all groups across the board. For instance, one policy should be enforced for students, teachers, staff, and visitors at all school-related functions, not merely on school grounds.
- When a nonsmoking policy is established without local support, compliance and enforcement may be problematic. Therefore, efforts to establish a nonsmoking policy should utilize a grassroots approach involving the community and youth in its planning, development, and implementation. Nearly all States are funded through either the National Cancer Institute's ASSIST (American Stop Smoking Intervention Study) program or the Centers for Disease Control and Prevention's IMPACT (Initiatives to Mobilize for the Prevention and Control of Tobacco Use) program to establish and implement such grassroots approaches.
- Prior to taking steps to establish tobacco-free environmental policies, it is recommended to research and identify policies that already exist, such as the Goals 2000: Pro-Children Act of 1994 (P.L. 103--227), which established a nonsmoking policy at sites housing such children's services as health care, day care, education, or library services.

### Recommendations for Prevention Approach 6: Restriction of Advertising and Promotion

The Expert Panels' recommendations regarding advertising and promotion restriction interventions focus on community partnerships and integration of messages:

- It is recommended that practitioners and even community groups not attempt to conduct these types of interventions in isolation. Rather, they should work in close partnership with community leaders, grassroots organizations, and members of the community. Aggressive attempts should be made to obtain acceptance of the interventions by community members and policymakers. Perhaps the most serious mistake is appearing to dictate how things will be done in the community. Cooperation on all levels is necessary.
- An important lesson learned from multicomponent prevention programs is that the components of such a program should be complementary elements with the same overall goal and philosophy. When no-tobacco or antitobacco messages are incorporated into event activities, they should be integrated with existing activities, messages, and promotions. They should not be merely add-on messages but should support other activities.
- The adaptation of these promising interventions to other social settings depends on a number of variables, such as the readiness of the community for such activities, the geographic area, and social and cultural support for prevention of tobacco use by adolescents.

## Community-Based Approaches: General Recommendations

Most of the panel's recommendations regarding prevention intervention research and practice are specific for a prevention approach. Several recommendations, however, are applicable to most community-based interventions designed to prevent tobacco use by adolescents.

Use Integrated Multicomponent Interventions. Community-wide antitobacco campaigns can promote antitobacco attitudes and behaviors among adolescents and their parents and can significantly reduce the rate of tobacco use by adolescents, especially if multiple prevention components are used. Indeed, research demonstrates that multicomponent community interventions are more effective than single interventions. On the practice side, it is recommended that practitioners utilize multicomponent interventions that involve the community and its organizations and agencies, its schools, and the media. Moreover, the elements of a multicomponent intervention should be integrated and should support and enhance each other. The scientific method emphasizes the importance of identifying intervention components that produce significant positive effects. On the research side, therefore, it is recommended that researchers investigate the effectiveness of individual intervention components.

Link Programs With Existing Activities. Communication should be established with programs and activities that are currently active with youth, especially high-risk youth. It is also important to identify individuals and organizations that are involved in adolescent health risk reduction, especially those related to substance use, as well as substance abuse prevention programs for adults. Similarly, linkages should be established with community social, cultural, and religious agencies and institutions, especially those that provide social services to the target audience or its family members.

Communication and collaboration with such community partners has several benefits: prevention activities become part of an existing network rather than existing in isolation, the likelihood of local acceptance and support of the prevention efforts is increased, the likelihood of duplication of effort and services is decreased, and community partners can often identify potential problems and recommend strategies for avoiding or solving them.

Involve Adolescents. Although they may not have as clear an understanding as adults of the causes and effects of different variables, adolescents have a distinctive understanding of the beliefs, attitudes, perspectives, and opinions of their peers. For this reason, adolescents can be particularly valuable in the design, planning, and implementation of intervention programs and research through vehicles such as focus groups, task forces, surveys, and interviews. Adolescents have valuable roles in many areas of intervention, such as merchant education, community education, peer education, curriculum development, and tobacco-free events. As a bonus, adolescent involvement in community-based and school-based prevention efforts is a tobacco-free alternative activity for them.

Adolescent involvement can be encouraged and supported by creating an open and supportive climate. Tobacco use intervention planners should collaborate with organizations and individuals that specialize in working with youth. Such specialized experience and knowledge should be incorporated into prevention intervention activities. In addition, these organizations have access to a wide range of youth, from accomplished youth leaders to youth considered to be at high risk for substance abuse.

Seek Sustained, Comprehensive Community Support. Both researchers and practitioners should make vigorous efforts to obtain support from the community. These efforts should not be limited to the early phases of an intervention, but should evolve into an ongoing process. Attempts should be made both to retain existing support and to continually seek new support. The support should be comprehensive and come from all vital community localities, such as prominent individuals, community leaders, representatives of the community's ethnic groups, community businesses, merchants, community organizations, students, student organizations, government agencies, and social associations. Support should be sought from government agencies, such as the mayor's office or its equivalent, social service agencies, the police, the judicial system, and the school system. Emphasis should be placed on an aggressive, ongoing partnership of community members.

Use Existing Materials. There exists a wealth of effective printed and audiovisual educational prevention materials regarding adolescents' substance use, much of it in the public domain. When such materials are available and appropriate for the target audience, using them can save time and money. Similarly, modifying existing prevention materials to more effectively meet the needs of a target audience is much less expensive than developing them from scratch. Existing educational materials that are appropriate for one audience may need to be revised to ensure their cultural sensitivity and appropriateness for another. Some programs expand or modify elements of an existing multielement educational program. When such materials include specific identifiers of the community, setting, and sponsors, the sense of partnership and ownership can be enhanced.

Educate Merchants, Law Enforcement Officials, and Judges. For community education components in youth access interventions, prevention efforts should include retail merchants, policy- and decisionmakers, the police, and the judicial system. Retail merchant education should include written materials for retail store owners and clerks and the regional executives of retail store chains. Ideally, these materials should be delivered in person by teams of representatives from the police department, adolescents, and others in the community. Prevention practitioners should aggressively pursue partnerships with the police and judges. Police in some areas are reluctant to enforce adolescent tobacco sales laws and may need persuasion. Similarly, judges are often reluctant to impose consequences on merchants for violating tobacco sales laws. With perseverance and by providing targeted information and education, however, the police and judges can become ardent supporters of prevention efforts.

Gather Data at All Stages. Prevention interventions and community efforts can easily be structured to generate data that are of value to researchers, prevention practitioners, State and local government officials, and the general public. Data collection is easiest and most productive when it is incorporated in the intervention design, not added as an afterthought.

Experience has shown that support from the community, government, and the media is made possible or enhanced when efforts are made to document the extent of the problem before an intervention is undertaken. For example, a city council may not be compelled to ban tobacco sales on city property and at city functions until it is proven that a problem exists. Conducting a baseline survey and providing this information to the community through forums, to the city council through presentations, and to the media through press conferences may increase the likelihood of support for such a ban.

Periodic surveys should be conducted to evaluate the effectiveness of the intervention. Ideally, such data collection should follow changes in the intervention. The collection of data can be an important aspect of continued community prevention activities. For example, surveys based on purchase attempts by adolescents in convenience stores can identify vendors that are complying with local laws. When such vendors are identified, they can be rewarded in several ways, such as publishing a brief article about them in a local paper, giving them gift certificates from other local merchants, or presenting them with awards at community events.

When limited funding for quantitative and qualitative analyses is a problem, it can be useful to enlist the help of staff at universities who may be able to recommend graduate researchers for assistance. However, since analyses conducted through a university will be time intensive, ample time should be allotted for these processes during the planning stages.

Traditionally, program evaluation involves the use of surveys and questionnaires that assume a certain level of literacy. They also often assume a certain level of English comprehension. Program evaluation techniques should therefore be developed that are appropriate for populations who speak little or no English and for those who have a low literacy level.

Prepare for Opposition. It is a fact of life that special interest groups are opposed to many tobacco prevention interventions. These groups, such as members of the tobacco industry, employ impressive legal, political, and media tactics. Community leaders should learn about oppositional strategies and then inform their staff and volunteers. Pro-smoking, mass media efforts by the tobacco industry are often tailored to regional conditions and interests. Therefore, communities should also consider their regional characteristics in developing counter strategies.

## References

Altman, D.G.; Foster, V.; Rasenick-Douss, L.; and Tye, J.B. Reducing the illegal sale of cigarettes to minors. Journal of the American Medical Association. 1989;261:80-83. [pmid: 2908999].
Altman, D.G.; Rasenick-Douss, L.; Foster, V.; and Tye, J.B. Sustained effects of an educational program to reduce sales of cigarettes to minors. American Journal of Public Health. 1991;81:891-893. [pmid: 2053666].
Bauman, K.E.; LaPrelle, J.; Brown, J.D.; Koch, G.G.; and Padgett, C.A. The influence of three mass media campaigns on variables related to adolescent cigarette smoking: Results of a field experiment. American Journal of Public Health. 1991;81:597-604. [pmid: 2014859].
Biglan, A.; Henderson, J.; Humphreys, D.; Yasui, M.; Whisman, R.; Black, C.; and James, L. "Experimental Evaluation of a Community Intervention to Reduce Youth Access to Tobacco." Unpublished manuscript, 1994a.
Biglan, A.; Ary, D.; Yudelson, H.; Duncan, T.; Hood, D.; James, L.; Koehn, V.; Wright, Z.; Black, C.; Levings, D.; Smith, S.; and Gaiser, E. "Experimental Evaluation of a Modular Approach to Media Campaigns for the Prevention of Adolescent Tobacco Use." Unpublished manuscript, 1994b.
Edwards, C.C.; Elder, J.P.; de Moor, C.; Wildey, M.B.; Mayer, J.A.; and Senn, K.L. Predictors of participation in a school-based anti-tobacco activism program. Journal of Community Health. 1992;17:283-289. [pmid: 1401235].
Elder, J.P.; Sallis, J.F.; Woodruff, S.I.; and Wildey, M.B. Tobacco-refusal skills and tobacco use among high-risk adolescents. Journal of Behavioral Medicine. 1993;16:629-642. [pmid: 8126716].
Feighery, E.; Altman, D.G.; and Shaffer, G. The effects of combining education and enforcement to reduce tobacco sales to minors: A study of four northern California communities. Journal of the American Medical Association. 1991;266:3168-3171. [pmid: 1956106].
Flay, B.R.; Hansen, W.B.; Johnson, C.A.; Collins, L.M.; Dent, C.W.; Dwyer, K.M.; Grossman, L.; Hockstein, G.; Rauch, J.; Sobel, J.L.; Sobel, D.F.; Sussman, S.; and Ulene, A. Implementing effectiveness trial of a social influences smoking prevention program using schools and television. Health Education Research. 1987;2:385-400.
Flynn, B.S.; Worden, J.K.; Secker-Walker, R.H.; Badger, G.J.; Geller, B.M.; and Costanza, M.C. Prevention of cigarette smoking through mass media intervention and school programs. American Journal of Public Health. 1992;82:827-834. [pmid: 1585963].
Flynn, B.S.; Worden, J.K.; Secker-Walker, R.H.; Pirie, P.L.; Badger, G.J.; Carpenter, J.H.; and Geller, B.M. Mass media and school interventions for cigarette smok-ing prevention: Effects 2 years after completion. American Journal of Public Health. 1994;84:1148-1150. [pmid: 8017542].
Forster, J.L.; Hourigan, M.E.; and Kelder, S. Locking devices on cigarette machines: Evaluation of a city ordinance. American Journal of Public Health. 1992a;82:1217-1219. [pmid: 1503160].
Forster, J.L.; Hourigan, M.; and McGovern, P. Availability of cigarettes to underage youth in three communities. Preventive Medicine. 1992b;21:320-328. [pmid: 1614994].
Glantz, S.A. Changes in cigarette consumption, prices, and tobacco industry revenues associated with California's Proposition 99. Tobacco Control. 1993;2:311-314.
Hinds, M.W. Impact of a local ordinance banning tobacco sales to minors. Public Health Reports. 1992;107:355-358. [pmid: 1594748].
Jason, L.A.; Ji, P.Y.; Anes, M.D.; and Birkhead, S.H. Active enforcement of cigarette control laws in the prevention of cigarette sales to minors. Journal of the American Medical Association. 1991;266:3159-3161. [pmid: 1956104].
Keay, K.D.; Woodruff, S.I.; Wildey, M.B.; and Kenney, E.M. Effects of a retailer intervention on cigarette sales to minors in San Diego County, California. Tobacco Control. 1993;2:145-151.
McKenna, J.W., and Williams, K.N. Crafting effective tobacco counteradvertisements: Lessons from a failed campaign directed at teenagers. Public Health Reports. 1993;108(Supp.1):85-89. [pmid: 8210278].
Murray, D.M.; Prokhorov, A.V.; and Harty, K.C. Effects of a Statewide antismoking campaign on mass media messages and smoking beliefs. Preventive Medicine. 1994;23:54-60. [pmid: 8016033].
Nelson, D.E.; Sacks, J.J.; and Addiss, D.G. Smoking policies of licensed child day-care centers in the United States. Pediatrics. 1993;91:460-463. [pmid: 8380925].
Pentz, M.A.; MacKinnon, D.P.; Dwyer, J.H.; Wang, E.Y.I.; Hansen, W.B.; Flay, B.R.; and Johnson, C.A. Longitudinal effects of the Midwestern Prevention Project on regular and experimental smoking in adolescents. Preventive Medicine. 1989a;18:304-321. [pmid: 2740299].
Pentz, M.A.; MacKinnon, D.P.; Flay, B.R.; Hansen, W.B.; Johnson, C.A.; and Dwyer, J.H. Primary prevention of chronic diseases in adolescence: Effects of the midwestern prevention project on tobacco use. American Journal of Epidemiology. 1989b;130:713-724. [pmid: 2788994].
Pentz, M.A.; Brannon, B.R.; Charlin, V.L.; Barrett, E.J.; MacKinnon, D.P.; and Flay, B.R. The power of policy: The relationship of smoking policy to adolescent smoking. American Journal of Public Health. 1989c;79:857-862. [pmid: 2735472].
Perry, C.L.; Crockett, S.J.; and Pirie, P. Influencing parental health behavior: Implications of community assessments. Health Education. 1987;October/November.
Perry, C.L.; Pirie, P.; Holder, W.; Halper, A.; and Dudovitz, B. Parent involvement in cigarette smoking prevention: Two pilot evaluations of the "Unpuffables Program.". Journal of School Health. 1990;60:443-447. [pmid: 2283873].
Peterson, D.E.; Zeger, S.L.; Remington, P.L.; and Anderson, H.A. The effect of State cigarette tax increases on cigarette sales, 1955 to 1988. American Journal of Public Health. 1992;82:94-96. [pmid: 1536343].
Popham, W.J.; Potter, L.D.; Hetrick, M.A.; Muthen, L.K.; Duerr, J.M.; and Johnson, M.D. Effectiveness of the California 1990-1991 Tobacco Education Media Campaign. American Journal of Preventive Medicine. 1994;19(6):319-326. [pmid: 7880550].
Skretny, M.T.; Cummings, K.M.; Sciandra, R.; and Marshall, J. An intervention to reduce the sale of cigarettes to minors. New York State Journal of Medicine. 1990;90:54-55. [pmid: 2304661].
Stevens, M.M.; Youells, F.E.; Freeman, D.H.; Linsey, S.C.; and Mott, L.A. Smokeless tobacco use among children: The New Hampshire Study. American Journal of Preventive Medicine. 1993;9:160-167. [pmid: 8347367].
U.S. General Accounting Office. Teenage Smoking: Higher Taxes Should Significantly Reduce the Number of Smokers: Report to the Honorable Michael A. Andrews, House of Representatives. GAO Pub. No. 89-119. Washington, DC: U.S. General Accounting Office, 1989.
Warner, K.E. Smoking and health implications of a change in the federal cigarette excise tax. Journal of the American Medical Association. 1986;255:1028-1032. [pmid: 3945014].
Werch, C.E.; Young, M.; Clark, M.; Garrett, C.; Hooks, S.; and Kersten, C. Effects of a take-home drug prevention program on drug-related communication and beliefs of parents and children. Journal of School Health. 1991;61:346-350. [pmid: 1787697].
Wildey, M.B.; Woodruff, S.I.; Agro, A.; Keay, K.D.; Kenney, E.M.; and Conway, T.L. Sustained effects of educating retailers to reduce cigarette sales to minors. Public Health Reports. 1995;110:625-629. [pmid: 7480619].

## Practice Cases Reviewed

- The Coalition Against Uptown Cigarettes. Philadelphia, Pennsylvania.
- The Coalition for a Tobacco-Free Monterey County: Monterey, California.
- The Colorado Tobacco-Free Schools and Communities Project of the Colorado School Health Council: Denver, Colorado.
- The Dover Youth Access to Tobacco Reduction Program of the Dover Police Depart-ment: Dover, New Hampshire.
- The Health Is Wealth project of the Asian Health Services: Oakland, California.
- The Multicultural Area Health Education Center project: East Los Angeles, California.
- The Pajaro Valley Prevention and Student Assistance program of the Pajaro Valley Unified School District: Wastonville, California.
- Project SCAN (Stop Children's Addiction To Nicotine): Erie County, New York.
- The Ski Tobacco-Free project of the Kirkwood Ski Education Foundation: Kirkwood Ski Resort, Alpine County, California.
- The Stop Teenage Addiction to Tobacco program of Stanford University School of Medicine: San Jose, California.
- The Stop Tobacco Access for Minors Project of the North Bay Health Resources Center: Sonoma County, California.
- The Tobacco-Free Soccer League Initiative Project of the Health Education Council: Sacramento, California.
- The Tobacco-Free Youth Project of the COMMIT to a Healthier Raleigh Project: Raleigh, North Carolina.