# Community-Based Prevention

Each year, more than 400,000 Americans die prematurely from smoking-related illnesses (Centers for Disease Control and Prevention 1993a). This number of fatalities is equal to that of the deaths of everyone on two completely loaded 747 jumbo jets crashing every day. It is more than all the deaths caused each year by suicide, homicide, automobile crashes, alcohol, illicit drugs, and AIDS combined. It is more than seven times the number of Americans who died during the entire course of the Vietnam War (McGinnis and Foege 1993; U.S. Department of Health and Human Services 1994).

Tobacco use reduces the quality of life for everyone in a community, whether they smoke or not. Apart from the more obvious health-related effects of tobacco use on individuals - both those who smoke and those exposed to secondhand smoke - there are less obvious overall economic effects of tobacco use on the community.

When an individual in a community or society becomes ill or dies prematurely, the community loses the human and economic contributions of that individual. The congressional Office of Technology Assessment (OTA) estimated that, on average, persons who died in 1990 due to smoking would have lived at least 15 additional years had they not smoked (Herdman et al. 1993). Each year, this premature mortality results in six million years of potential life lost for the U.S. population. While calculations of the health care costs of tobacco use vary, OTA estimated that in 1990 the expenditures included $20.8 billion in direct health costs, $6.9 billion in lost productivity due to disease, and $40.3 billion in lost productivity due to premature deaths. For 1993, the direct health care cost of tobacco use was estimated to be $50 billion (Centers for Disease Control and Prevention, 1994). Everyone in a community is affected by these costs, whether directly as a family member or indirectly through increased medical and tax expenditures (Institute of Medicine 1994).

Generally speaking, community-based approaches aimed at reducing the incidence of certain health problems seek small but pervasive changes that apply to the majority of a population (Green and Kreuter 1991). Community-based approaches are aimed at ameliorating the quality-of-life and economic costs of illness to society. Practitioners can use these approaches to address the environmental and behavioral risk factors for tobacco use among youth identified in Chapter 1. For example, practitioners can design community-based approaches to change community perceptions of the acceptability of tobacco use among youth or to improve the ability of youth to refuse tobacco products when offered by friends.

For community-based prevention approaches to be most effective requires an understanding of the basis for and the advantages of choosing community-based approaches over individual-centered approaches. This chapter reviews tobacco use among youth within the context of the larger community and presents a rationale for community-based approaches to prevention.

Each year smoking-related illnesses claim the lives of more Americans than all other major causes of death combined.

## Tobacco Use Among Youth as a Community Problem

When young people smoke, they are often initiating a history of smoking that will eventually cost them and the rest of society huge amounts of money for health care. Health care costs are the fastest growing costs in our society. Communities have reason to be concerned about the use of tobacco products by youth because of the short- and long-term health consequences of tobacco use (see Chapter 1) as well as the associated health care costs. Likewise, community members have reason for concern when behavior that ultimately claims so many lives is being practiced by their own children and by their neighbors' children.

Very few communities, however, have labeled the use of tobacco products by youth as a community problem. There is nothing communities could do that would have more far-reaching effects on the health and safety of youth than making prevention of tobacco use a top priority (U.S. Department of Health and Human Services 1994). The sale and distribution of tobacco products to youth are illegal. Most communities have no difficulty generating broad-based concern about use of other substances, such as alcohol, marijuana, LSD, cocaine, and heroin, by youth. But most communities do not view tobacco use by youth as a drug use problem, despite the fact that nicotine can be an addictive drug like alcohol, marijuana, heroin, and cocaine. In fact, there is some evidence that a larger percentage of people who experiment with nicotine become dependent on it than is true for cocaine experimentors (Henningfield et al. 1990; U.S. Department of Health and Human Services 1988). In the light of such evidence, communities should redefine their concerns about the use of illicit drugs to include tobacco products.

Moreover, research has shown that unhealthy and risky behaviors seem to cluster in some individuals (Clayton 1992; Jessor and Jessor 1977). Cigarette use, for example, may be a marker for the use of other drugs. Of 12- to 17-year-olds who currently smoke cigarettes, 25 percent have used marijuana in the past month (SAMHSA 1994). Of 12- to 17-year-olds who do not currently smoke, only 2 percent have used marijuana in the past month. The same degree of statistical association exists between cigarette smoking and various other problem behaviors, such as delinquency, risky sexual behavior, fighting, aggression, carrying and using weapons, and other forms of violence (Centers for Disease Control and Prevention 1993b).

## Rationale for Community-Based Programs

All of us live in communities. We share values with our neighbors, such as wanting our children to be safe and healthy. To that end, we protect our children in several ways. Many States and communities have implemented mandatory seat belt laws to protect us and our young people from being injured or killed in traffic incidents. Virtually all States and communities have implemented and enforced laws that prohibit the sale of illicit drugs within a certain distance of schools. Many school systems have installed metal detectors to protect our young people from being hurt by weapons taken to school. Quite a few communities give full support to special drug prevention events, such as Red Ribbon Week and Project Graduation.

For most of the 20th century, the approach to preventing substance abuse has focused on the individual rather than on his or her environment. This individual-centered approach assumes that the most important causes of substance abuse, including tobacco, lie within the individual - in his or her attitudes, values, and personality (Gerstein and Green 1993; Hansen 1992). This assumption does not fully take into account the fact that individuals exist and function in a variety of environmental contexts. Each exerts an influence on attitudes, behavior, and perceptions of the norms of appropriate and inappropriate behavior.

The past two decades have been marked by an increasing awareness of the importance of focusing on the environmental contexts of substance abuse as well as on the individual. In terms of tobacco use among youth, these contexts may include use by peers, siblings, and parents or images of tobacco use promulgated by media and advertising. Within these and other environmental contexts, the use of tobacco or other substances acquires additional levels of meaning beyond those that relate strictly to the individual (e.g., self-esteem or a subjective sense of well-being). Within these environmental contexts exist modifiable elements that, when addressed, can alter the social structures that provide opportunities to use tobacco or other drugs.

### Individual-Centered Approaches

A number of interventions have been designed to delay the start of smoking or to persuade young people not to continue to smoke. Nearly all of these have focused on the individual and have been school based and curriculum driven. The state-of-the-art approach is the social influences model. School programs based on the social influences model generally have the following components in common (Hansen 1992):

- Use of information on the short- and long-term health and social consequences of smoking and on the social factors that influence smoking
- Discussion of the influence of peers, family, and the media on smoking and ways to deal with them
- Modeling, typically using video or film or peers to show these influences and situations, along with coping behaviors
- Role playing and learning of behavioral skills
- Public commitment regarding smoking intention

Most curricula on social influences or peer resistance either explicitly or implicitly incorporate methods for enhancing a young person's perceived self-efficacy (Gerstein and Green 1993; Pentz et al. 1989a) by:

- Specifying explicit near-term goals
- Promoting performance accomplishments through participation and practice
- Providing models of successful resistance behavior
- Providing task-specific feedback that reinforces and validates successful performance

These types of programs focus intensely on changing the potential smoker's attitudes, knowledge, perceptions, and intention with regard to smoking (Best et al. 1984; Brook et al. 1992; DiFranza 1989; Flay et al. 1989; Gerstein and Green 1993; Hawkins and Weis 1985; Leventhal et al. 1991; Pentz et al. 1989b; Perry et al. 1992; Scheier and Newcomb 1991). In addition, youth are assembled together in schools and are accustomed to learning through curricula.

However, there is evidence that the effects of these prevention programs that dissipate over time can be enhanced with booster sessions to extend the effects throughout the high school years. In addition, the effectiveness of school-based programs appears to be enhanced by community-wide programs that utilize the positive social influences of parents, community organizations, and mass media.

Some of these programs have shown evidence of a short-term delay in beginning smoking. A few such programs report modest, though statistically significant, long-term effects. In virtually all of the studies of the long-term effects of well designed smoking prevention programs to date, however, the effects have been shown to be temporary. Within 5 to 7 years after the intervention, the prevalence of smoking among those who were "inoculated" against it has been the same as that for those who were not inoculated (Botvin et al. 1993; Resinow and Botvin 1993).

### Community-Based Approaches

In this discussion of community-based approaches, the term community is comprehensive and includes large cities, small towns, schools, worksites, and public places. For a community approach to be successful, certain criteria regarding the health problem and methods to change it must be met (Green and Kreuter 1991; Puska et al. 1985). Following are some of these criteria:

- The health problem, behavior, or condition must be pervasive in a given community.
- A majority of the factors that affect the problem must be external to the individual (i.e., social or environmental).
- It must be possible to change the health problem through community channels.
- The magnitude and nature of the problem must preclude a simple, externally imposed solution.
- The community must be ready to change the problem.

For most communities, the first four of these criteria are met for the problem of tobacco use among youth. Most youth have either tried tobacco or use it on a regular basis. The factors affecting this use include permissiveness toward use of tobacco and general accessibility to tobacco products by youth. Community forces can be mobilized to change the health problem; for example, city councils have passed ordinances to enforce laws that prohibit tobacco sales to minors. Simple environmental solutions such as enacting no-smoking policies, however, are not sufficient to reduce tobacco use by adolescents. Indeed, while none of the approaches described above are sufficient when used alone, they are worthwhile, especially when delivered in the context of a multicomponent prevention campaign.

Community readiness to address the problem varies considerably nationwide. The community-based approach, however, includes methods to ready the community for change, thereby beginning the process of solving the problem.

#### Cost-Effectiveness

Although community approaches often require more resources than do individual-focused approaches, there are advantages to community approaches that can make it more cost-effective over the long term. The most important of these is the potential for synergism, a multiplicative intervention effect, with the use of multiple strategies. A community approach with multiple components that are designed to be complementary may be more effective than individual-focused strategies designed in isolation (Farquhar et al. 1990). Other advantages of community-based intervention approaches include the following (Farquhar et al. 1990; Green and Kreuter 1991; Puska et al. 1985; Thompson et al. 1991):

- They are particularly effective when inherently efficient intervention channels, such as mass media, are used.
- They can result in extensive population-wide changes in health behavior or health status.
- They involve a greater number and diversity of people and organizations in the community that can provide greater support for the desired change and can promote change among community members who might never be reached by an individual approach.
- They enhance the possibility of altering behavioral norms and environmental factors, such as regulations.
- Participation by multiple organizations and volunteers can reduce the funds needed to implement intervention activities.
- They form an important link between basic laboratory and clinical research and the large-scale application of public health programs by:
  - - Diminishing uncertainty concerning the effectiveness of an approach by implementing it in practice
  - - Informing practitioners about the effective use of prevention resources
  - - Identifying unintended consequences of program implementation
- They can result in sustained community change and organization once the effort has been adopted by the community.
- They target multiple groups for behavior change (i.e., parents, youth, merchants, public officials, law enforcement) based on the knowledge that responsibility for addressing the problems is shared by many, not just youth. These interventions also address the social origins of the problem, helping to avoid blaming the victim.

These advantages have been validated in several areas of public health community research, including the prevention of cardiovascular disease, smoking cessation approaches, and local approaches to the control of alcohol availability (Farquhar et al. 1990; Green and Kreuter 1991; Puska et al. 1985; Thompson et al. 1991). Perhaps the most instructive community-based programs have been those implemented to prevent cardiovascular disease. Well-known examples of studies in this area are the Stanford Five Cities Project (Farquhar et al. 1990), the North Karelia Project (Puska et al. 1985), and the Minnesota Heart Health Program (Luepker et al. 1994). Each of these programs resulted in considerable community involvement and acceptance of the program. Important components of these programs include organization and education of communities or cities regarding the importance of preventing heart disease, media messages through multiple channels, and the active participation of community members in the project. Both the Stanford and North Karelia projects resulted in significant changes in the risk status of members of the intervention communities. Although the same findings were documented in the Minnesota program, the comparison communities also modified their behavior (probably due to healthy lifestyle changes), resulting in virtually no difference in risk status between intervention and comparison communities.

#### Advantages

The community-based approach has certain advantages over an individual-centered approach to prevent tobacco use; these advantages are outlined in the following sections.

##### Coverage

The first and most obvious advantage of community-based programs is coverage. As an example, one community-based approach for reducing tobacco use by youth involves the requirement that anyone involved in any way with the sale and distribution of tobacco products participate in a merchant education program (Feighery et al. 1991). This would cover all outlets for tobacco products, so that the focus of the intervention would be on the point of purchase instead of on individuals who might want to obtain cigarettes or other tobacco products. The coverage or exposure of the prevention effort is enhanced because of the intervention target.

##### Maximization of Resources

A second obvious advantage of community-based efforts is that they maximize the efficient use of scarce resources while minimizing costs. For example, in a community of 750,000, there might be between 70,000 and 90,000 students. To provide an effective individual-based program for smoking prevention would require a large number of person-hours of involvement in teaching the curriculum. Providing merchant education about the requirements of the law and how to resist selling tobacco products to minors, however, would require far less effort and money, primarily because there are fewer clerks than there are potential underaged buyers (Woodruff et al. 1993). In addition, the material to be learned is less extensive and complex.

Maximization of Outcomes. The third obvious advantage of community-based prevention efforts over individual-centered approaches is the potential for maximizing outcomes. The utility of community approaches lies in the fact that they can be focused on policy changes. Policies dictate how business is conducted, regardless of the setting (school, workplace, community) and provide clear parameters of what is and is not acceptable. The likelihood of reducing tobacco use by adolescents depends partly on the uniformity of standard operating procedures.

For example, the school board in a community might make the reduction of tobacco use by youth a top priority (Johnson et al. 1990; Pentz et al. 1989c). The school board could adopt a policy for all teachers, other staff, and students of no smoking anywhere on campus at any time. This type of policy is clear and unambiguous. It covers all environmental settings that fall under the category of "school." It covers all roles - students, teachers, administrators, coaches, custodians, and cafeteria workers - within that environmental context. If smoking is not allowed anywhere on campus, even during off-hours school events, there will be a good likelihood of achieving the desired outcome.

Visibility. The fourth advantage of community-based approaches is their visibility and repetitive reinforcement, which strengthens norms against tobacco use by youth. One of the most visible and effective tobacco use prevention efforts was California's Proposition 99. This legislation enabled two statewide approaches - an increase in the State tax on tobacco products and a counteradvertising campaign with many mass media public service announcements (Glantz 1993). Youth in California received multiple, reinforcing messages about the expense and dangers of tobacco use. In addition, the legislation funded local community groups, such as boys' and girls' clubs.

Finally, in summarizing the advantages of community-based approaches, one cannot overlook their synergistic effect in reaching various targets within the community.

## Sociological Framework for Tobacco Control

Legal and social norms concerning the use of tobacco products have undergone major changes in the last 100 years. During the first three decades of the 20th century, smoking was disapproved of as inappropriate for minors. Smoking by minors was considered a sign of delinquent tendencies and even legally defined in many jurisdictions as a form of delinquency (Troyer and Markle 1983). From the 1930s to the 1960s, smoking became acceptable, even fashionable, in many segments of society. By the 1960s, teenage smoking was widespread and generally not viewed as a problem.

Recently, however, there has been a major shift in the United States toward greater disapproval of smoking by minors (Markle and Troyer 1979; Neuhring and Markle 1974; Troyer and Markle 1983). This shift is due to the body of overwhelming scientific evidence about the health effects of smoking, broad-based concern about and efforts to eliminate drug use among adolescents, and an increasing level of concern about and intolerance of smoking in general.

The social context in which tobacco products exist, however, is changing dramatically, as reflected by events in the summer of 1994: The Commissioner of the Food and Drug Administration (FDA) publicly raised the issue of whether it should regulate products containing nicotine because nicotine is an addictive drug (Kessler 1994). In nationally televised hearings, representatives of the tobacco industry were taken to task for suppressing information that could establish the abuse liability of nicotine. Since then, numerous State liability suits have been filed, several Department of Justice actions have been taken against the tobacco industry related to perjury charges, and the FDA final rule has been released.

The social context of the use of tobacco products in the United States has undergone a shift from being socially acceptable to recognition that tobacco use is a major public health problem. In many ways, being tobacco-free is seen as the norm. Tobacco users are faced with vast amounts of information on the negative health effects of tobacco use and are subject to increasing restrictions designed to protect nonsmokers from the harmful effects of tobacco smoke.

### Importance of Social Context

Tobacco control is the term used to describe the range of efforts employed to regulate tobacco products (Altman et al. 1992). Tobacco control efforts have been implemented at all levels of government (Bal et al. 1990; Centers for Disease Control and Prevention 1991; Choi et al. 1991) and consist primarily of the following types of activities:

- Imposition of sales taxes on the product (Coalition on Smoking OR Health 1993)
- Requirements for warning labels on each package
- Restrictions on advertising of the products (Ericksen et al. 1990; Flay 1987; Pierce et al. 1991)
- Regulation and licensing of outlets that distribute tobacco products through over-the-counter or vending machine sales (Barovich et al. 1991; Centers for Disease Control and Prevention 1992b; Cummings et al. 1992; Feighery et al. 1991; Forster et al. 1992)
- Restrictions on where, when, and by whom the products can be used
- A minimum age requirement for purchase of the products (Davis and Jason 1988; Hoppock and Houston 1990)

In most communities, tobacco control has consisted primarily of activities designed to increase awareness of the consequences of smoking, advocacy of restrictions on smoking, and smoking cessation programs. The most readily recognized activities include the American Cancer Society's yearly Great American Smoke-Out, advocacy campaigns for reducing the number of places where people are allowed to smoke, and the smoking cessation programs offered by the American Cancer Society, the American Lung Association, and the American Heart Association. Although the prevalance of lifetime experience with cigarettes declined steadily from 1975 to 1990, it now appears to be on the rise (Institute of Medicine 1994). Because there are still 50 million people who smoke in the United States (SAMHSA 1994), this is an extremely important target for tobacco control efforts.

As the number of smokers who successfully quit levels off, those who continue to smoke are likely to be the most addicted. Although targeting chronic smokers should remain a priority, the next greatest gain in lowering the number of smokers will likely come from efforts aimed at preventing initial nicotine addiction, such as stringent regulations governing advertising and youth access, and by reducing the appeal of tobacco products to youth.

Examples of such initiatives are mass media campaigns that address adolescents' tobacco-related attitudes and provide information about the effects of smoking, increases in Federal and State tobacco taxes, reduction of access to tobacco products by adolescents at retail outlets, enactment of tobacco-free environment policies to reduce adolescents' exposure to pro-tobacco messages, and implementation of policies that prohibit tobacco sponsorship of sporting and other events and reduce the number of tobacco advertisements to which youth are regularly exposed.

The social context of tobacco control depends on several factors:

- Number of Tobacco Users - Twenty-five percent of the U.S. population aged 18 years or older smokes (Federal Trade Commission 1995); this figure is down from 31 percent in 1985 and 26 percent in 1992. An estimated 6.1 million Americans, 2.9 percent of the population aged 12 and older, were current users of smokeless tobacco in 1993 (Hugick and Leonard 1991; National Institute on Drug Abuse 1992; Substance Abuse and Mental Health Services Administration 1994).
- Laws and Regulations - A critical mass of laws and regulations has been imposed on tobacco as a commercial commodity (see Boxes 2-1, 2-2, 2-3). The passage of the Synar Amendment (which requires States to demonstrate good-faith efforts to prevent the sale of tobacco to minors) and the movement by the FDA toward defining nicotine as an addictive drug suggest a tightening of Federal regulations on tobacco (Kessler 1994, U.S. Department of Health and Human Services 1990).
- Federal, State, and Local Initiatives - Communities are increasing the number of restrictions on the use of tobacco products in public places, choosing to limit or even ban smoking in restaurants and on all forms of public transportation (Gallup and Newport 1990). The Federal Government supports and encourages State initiatives through the funding of studies and programs such as the American Stop Smoking Intervention Study (ASSIST), funded by the National Cancer Institute, and Initiatives to Mobilize for the Prevention and Control of Tobacco Use (IMPACT), funded by the Centers for Disease Control and Prevention. A number of States have also filed lawsuits against the tobacco industry. In addition, the Robert Wood Johnson Foundation, through the American Medical Association, is funding State initiatives for tobacco control. These projects include helping States strengthen their tobacco policies and providing prevention education and information resources on health problems and tobacco.

BOX 2-1: Two Sets of Tobacco Regulations

Both the Substance Abuse and Mental Health Services Administration (SAMHSA) in the Department of Health and Human Services (DHHS) and the Food and Drug Administration (FDA) have taken steps to address the serious public health problems caused by young people's use of and addiction to tobacco products.

But why two sets of regulations?

The answer to that question lies in an examination of the focus of these two sets of rules. While the final rule issued by SAMHSA is directed to the States, the FDA proposal focuses on the tobacco industry and retailers.

The 1992 Synar Amendment mandated that all States enact and enforce laws barring the sale and distribution of tobacco products to minors. But a mechanism to ensure compliance with the amendment was absent. Even though all States outlaw tobacco sales to anyone under the age of 18, these laws are not strictly enforced. SAMHSA developed regulations designed to pressure States to enforce the amendment by decreasing the annual Substance Abuse Prevention and Treatment Block Grant award for States that did not comply with the enforcement and reporting requirements and totally withholding block grant funds from the States that did not enact the required prohibitions.

The SAMHSA regulations (see Box 2-2) were written in anticipation of passage of the FDA tobacco regulations (Box 2-3), which further enhance the Synar Amendment by not only making the sale of cigarettes and smokeless tobacco to anyone under 18 years of age a Federal violation but by placing limits on tobacco advertising and essentially banning self-service displays and vending machines.

In short, both sets of regulations ban the sale of cigarettes and smokeless tobacco to minors. Additionally, the FDA regulations place limits on marketing and distribution, and the SAMHSA regulations promote compliance by the States.

SOURCE: U.S. Department of Health and Human Services, Substance Abuse Prevention and Treatment Block Grants: Regulations for Sale or Distribution of Tobacco Products to Individuals Under 18 Years of Age, Federal Register, Aug. 23, 1993; Food and Drug Administration, Executive Summary, The Regulations Restricting the Sale and Distribution of Cigarettes and Smokeless Tobacco to Protect Children and Adolescents, August 1996.

BOX 2-2:Substance Abuse Prevention and Treatment Block Grants: Regulations for Sale or Distribution of Tobacco Products to Individuals Under 18 Years of Age - a Summary of the SAMHSA Tobacco Regulation

In 1993, the Substance Abuse and Mental Health Services Administration (SAMHSA) submitted to the Federal Register for publication its final regulation implementing Section 1926 of the Public Health Service Act prohibiting the sale or distribution of tobacco products to minors.

After considering comments received from the health community, State agencies, and tobacco product manufacturers and retailers, the SAMHSA regulation was finalized as a key component in the strategy to reduce tobacco use by youth.

Designed to implement the Synar Amendment while complementing FDA regulations that further expand the effort to relieve problems related to tobacco use, the regulation requires States to

- Enact a law prohibiting any manufacturer, retailer, or distributor of tobacco products from selling or distributing such products to any individual under the age of 18.
- Enforce the law in a manner that can reasonably be expected to reduce the availability of tobacco products to individuals under the age of 18.
- Conduct annual random, unannounced inspections of a valid sample of outlets accessible to youth to ensure compliance with the law.
- Develop a strategy and time frame for achieving an inspection failure rate of less than 20% of outlets accessible to youth.
- Report annually as part of the block grant application, detailing the State's activities to enforce the law and its success during the previous fiscal year in reducing tobacco availability to youth, describing how inspections were conducted and the methods used to target outlets, as well as plans for enforcing the law in the coming fiscal year.

The Secretary of DHHS is required by statute to withhold all funds from States that have not enacted the required prohibitions and to decrease the annual Substance Abuse Prevention and Treatment Block Grant award for States that do not comply with the enforcement and reporting requirements.

SOURCE: U.S. Department of Health and Human Services, Substance Abuse Prevention and Treatment Block Grants: Regulations for Sale or Distribution of Tobacco Products to Individuals Under 18 Years of Age, fact sheet, August 1993.

Despite major advances in communicating the health consequences of tobacco use, changes in the laws and regulations concerning tobacco as a commodity, and widespread State and local initiatives to restrict smoking, the social context of tobacco control is not unidirectional. There are numerous groups emerging to defend "smokers' rights." The tobacco industry spent more than $6 billion on advertising in 1993 (Federal Trade Commission 1995). Despite a ban on advertising tobacco products on television, it is impossible to escape manufacturers' logos on weekend television because they sponsor sporting events that are shown for several hours at a time (Blum 1991). There also has been a proliferation of cups, shirts, and hats carrying tobacco logos (Altman et al. 1991; Barovich et al. 1991; DiFranza et al. 1991; Fischer et al. 1991).

Moreover, despite grassroots efforts to restrict smoking, lobbyists for the tobacco industry have been able to blunt further restrictions on smoking by some State legislatures. They continue to do so through two legislative methods.

The first method, preemption, would place tobacco control at the State rather than the local level. Many of the most restrictive ordinances on access to tobacco by youth and smoking in public places have been adopted by cities and counties. In an effort to rescind these ordinances, the tobacco industry lobbies State legislatures to adopt less restrictive laws preempting the local ordinances.

The second method, changes in earmarking of State tobacco tax revenues, seeks to weaken the effect of increases in State taxes on tobacco products. Recently, the States of California and Massachusetts increased taxes on tobacco products and earmarked a portion of these funds for tobacco use prevention initiatives. In California, the increase in taxes and a prevention media campaign significantly reduced tobacco use by adolescents (Glantz 1993). After the first several years of the campaign, the tobacco industry successfully lobbied to reduce funding for the media campaigns and put more of the tobacco revenues into general health funds. Concurrently with the reduced prevention efforts, the initial decline in tobacco use among youth in California leveled off. In Massachusetts, a combination of tobacco industry lobbying and State revenue shortfalls resulted in the diversion of tobacco tax funds from tobacco use prevention to general health funds (STAT 1994).

On a more positive note, the governor of Massachusetts signed into law an amendment to the 1995 budget that allows the State's Attorney General to sue tobacco companies for recovery of Medicaid expenditures attributable to tobacco-caused diseases (STAT 1994). Massachusetts was the second State to enact such a law. The first, Florida, enacted the Medicaid Third-Party Liability Act, which was aimed at cigarette manufacturers and has been challenged as unconstitutional by Phillip Morris, Inc.; Associated Industries of Florida, Inc.; Publix Supermarkets, Inc.; and the National Association of Convenience Stores, Inc. (STAT 1994). Numerous States and several local jurisdictions have filed similar suits.

BOX 2-3:Regulations Restricting the Sale and Distribution of Cigarettes and Smokeless Tobacco to Protect Children and Adolescents - a Summary

The August 1996 publication of a final rule on tobacco in the Federal Register mandates that the Food and Drug Administration (FDA) regulate the sale and distribution of cigarettes and smokeless tobacco to children and adolescents.

The rule prohibits the sale of cigarettes and smokeless tobacco to those under 18 while leaving them on the market for adults.

Restricting Access by Children and Adolescents

- Minimum Age - The regulation prohibits retailers from selling cigarettes and smokeless tobacco to anyone younger than 18 years of age. Retailers must verify that purchasers are 18 or older by checking identification that includes the bearer's date of birth and photograph.
- Minimum Package Size - The regulation establishes 20 cigarettes as the minimum package size.
- Vending Machines - Vending machine sales of cigarettes and smokeless tobacco are prohibited except where the retailer or operator ensures that no person younger than 18 is present or permitted to enter at any time.
- Self-Service Displays - The use of self-service displays of tobacco products is prohibited except where retailers ensure that persons under the age of 18 are not present at any time.
- Mail-Order Sales and Coupon Redemption - Mail-order sale of tobacco products to adults is allowed; however, the FDA will monitor sales. Coupon redemption for free or discounted cigarettes through the mail is not allowed. Adults are allowed to receive coupons through the mail but must redeem them in person.
- Free Samples - The distribution of free cigarette or smokeless tobacco samples is prohibited.

Reducing the Appeal of Advertising to Children and Adolescents

- Billboards Near Schools and Playgrounds - Tobacco advertisements on billboards and other outdoor advertising are prohibited within 1,000 feet of elementary and secondary schools and public playgrounds.
- Text-Only Format - Cigarette and smokeless tobacco advertising is limited to black text on a white background, with two exceptions: in publications with a primarily adult readership and in adult-only facilities.
- Sale and Distribution of Non-Tobacco Items and Services - The tobacco industry is prohibited from disseminating any non-tobacco item or service that identifies that item or service with tobacco products, such as shirts, caps, and sporting goods.
- Sponsorship of Events - Tobacco companies are prohibited from sponsoring any sporting, cultural, or other event using a brand name, logo, colors, or anything else that would associate that event with particular cigarettes or smokeless tobacco. However, tobacco companies may sponsor events in the corporate name.

Educating People About Health Risks

Section 518(a) of the Federal Food, Drug, and Cosmetic Act requires device manufacturers to notify users about an unreasonable risk of substantial harm posed by a device. Because cigarettes and smokeless tobacco are now classified as nicotine delivery devices, the six major tobacco companies will be notified by the FDA that a national multimedia campaign advising the public of the dangers posed by cigarettes is required.

Relationship Between Federal and State and Local Laws

State and local laws pertaining to the sale and distribution of cigarettes and smokeless tobacco that differ from or add to Federal requirements are preempted. State and local laws unrelated to the rule, such as restrictions on smoking in restaurants, are not affected.

Analysis of Economic Impact

The rule is expected to produce significant health-related benefits, saving between $28 billion and $43 billion per year. The FDA estimates that the rule will impose one-time costs of between $174 million and $187 million per year and recurring annual operating costs of between $149 million and $185 million. The agency will monitor the effectiveness of the regulations and the extent to which individual provisions are followed.

Implementation

Most provisions of the rule go into effect one year after publication in the Federal Register, with two major exceptions: Six months after publication, retailers must begin enforcing the 18-year-old minimum age provision by checking the purchasers' identification and, because most sponsorship contracts are long term, companies will have 2 years to meet the requirement that prohibits sponsorship of events in the name of a tobacco product.

SOURCE: U.S. Food and Drug Administration, Executive Summary: The Regulations Restricting the Sale and Distribution of Cigarettes and Smokeless Tobacco to Protect Children and Adolescents, August 1996.

It is clear, however, that the social context for tobacco control for youth, although not entirely positive, is as good as it has ever been. Virtually no one, including those in the tobacco industry, openly advocates the use of tobacco products by adolescents, and this is a key element of the potential for change (Slade 1993). Opponents of tobacco control attempt to divert attention from the use of tobacco products by adolescents by raising issues such as the economic benefits associated with growing, selling, advertising, and taxing tobacco; protecting commercial free speech; and protecting the vanishing family farm.

### Assessing Community Readiness

Teenagers have been a primary target of tobacco use prevention efforts (Pentz et al. 1989a, 1989b, 1989c), reflecting societal concern about drug use among adolescents. This concern was reflected at the Federal level by the passage of the 1992 Synar Amendment (Davis and Jason 1988; Flynn et al. 1992). Readiness to prevent adolescent use of tobacco is more variable at the State and local levels (Centers for Disease Control and Prevention 1992a; Forster et al. 1992; Jason et al. 1991; Peterson et al. 1992).

Social context is important in assessing prevention readiness at the State and local levels. The degree of support for or resistance to identifying youth tobacco use as a significant social problem in the community depends largely on its social context within the community (Akers 1992). Oetting et al. (1994) have developed a model for assessing community readiness for change based on existing models for effecting change in individuals and in communities. Their model is an adaptation of the stages-of-behavior-change model (Owen et al. 1992; Prochaska et al. 1992), innovation theory (Rogers 1983) and the social action process (Beal 1964; Rogers et al. 1989; Warren 1978; Wells 1990). Stages of community readiness for prevention provide an appropriate framework for understanding prevention readiness at the community or State level (Oetting et al. 1994):

1. Community tolerance is present when community norms actively encourage the behavior, which is viewed as socially acceptable.
2. Denial is the stage in which the behavior is not usually approved of according to community norms. At this stage, people are aware that the behavior is a problem but believe that nothing needs to or can be done about the behavior at a local level.
3. Vague awareness is the stage in which there is a general feeling that the behavior is a local problem that requires attention. However, knowledge about the extent of the problem is sparse, there is little motivation to take action to prevent it, and there is a lack of leadership to address it.
4. In the preplanning stage there is a clear recognition that a problem with the behavior exists locally and that something should be done about it. At this stage, general information on the problem is available and local leaders needed to advance change are identifiable, but no real planning has occurred.
5. Preparation is the stage in which plans are being made to prevent the problem, leadership is active, funding is being solicited, and program pilot testing may be occurring.
6. Initiation is the stage in which a prevention program is under way but is still "on trial." Community members often have great enthusiasm for the effort at this stage because obstacles have not yet been encountered.
7. Institutionalization of prevention is when several programs are supported by local or State governments with established (but not permanent) funding. Although the program is accepted as a routine and valuable practice at this stage, there is little perceived need for change or expansion of the effort.
8. Confirmation/expansion is the stage in which existing programs are viewed as effective and authorities support expansion or improvement of prevention efforts. Data are routinely collected at this stage, and there is a clear understanding of the local problem and the risk factors for the problem. New programs are being planned to reach other community members at this stage.
9. In the professionalization stage, detailed information has been gathered about the prevalence, risk factors, and etiology of the local problem. At this point, various programs designed to reach general and specific target audiences are under way. Highly trained staff run the program and community support and involvement are strong. Also at this stage, effective evaluation is conducted to assess and modify programs.

### The Future for Tobacco Control

If the recent past is an accurate base for charting future trends, there will be an acceleration of efforts to regulate and control tobacco at the Federal, State, and local levels (Bal et al. 1990; Centers for Disease Control and Prevention 1991; Coalition on Smoking OR Health 1993; Kessler 1994; Peterson et al. 1992; Pierce et al. 1993). This is particularly true for access to and use of tobacco by youth. Because of the sanctions in the Synar Amendment, any State not demonstrating progress in limiting youth access to tobacco products with sound and measurable indicators may lose some of its Federal funding for substance abuse prevention and treatment programming. This will be a strong incentive, even for States in which tobacco is a viable part of the local economy.

The future of tobacco control will primarily be affected by three factors:

- Increasing Public Recognition of Addictive Properties of Nicotine. With mounting scientific evidence about the consequences of tobacco use, arguments against restrictions on access to and use of tobacco will increasingly be seen as specious and obstructionist. In addition, recognition of nicotine as addictive will tend to reduce the regulatory distinction between legal and illegal drugs (Benowitz 1992; Henningfield et al. 1991; Hughes and Hatsukami 1986; McNeill 1991).
- A Possible Reduction in the Number of People Who Smoke. If the percentage of tobacco users continues to decline, the number of people who might resist further restrictions on smoking will be smaller and thus less powerful (although backlash by smokers, local retailers and restaurant owners, and/or the tobacco industry is possible). Several recent polls have revealed that even people who smoke favor restrictions, especially if they would prevent youth from using tobacco (National Institute on Drug Abuse 1992; U.S. Department of Health and Human Services 1994).
- Diminishing Influence of the Tobacco Industry on the Federal, State, and Local Legislative and Executive Branches of Government. As the perceived influence of the tobacco industry decreases, the social context for regulation and control of tobacco, especially its use by adolescents, will be more positive. In the summer of 1994, the FDA Commissioner called for movement of the regulatory control of cigarettes to the FDA (Kessler 1994). The FDA followed this pronouncement with proposed regulations on the sale, distribution, and advertising and promotion of cigarettes (21 C.F.R. Part 801 ff. 1995).

The social context for preventing or reducing the use of tobacco by adolescents has never been more positive. Unfortunately, the problem of tobacco use by adolescents is substantial (Clayton and the Ann Arbor Group 1994; Johnston et al. 1994) and daunting from many perspectives. In the next section of this chapter, a rationale for community-based programs to address this challenge is presented.

## Single- and Multiple-Component Programs

Prevention programs can be designed with single or multiple components. A single-component program might be a school-based smoking prevention curriculum taught in 10 lessons during the last year of elementary school (5th or 6th grade). One benefit of such a program lies in attribution of outcomes (Johnson et al. 1990; Pentz et al. 1989b, 1989c; Perry et al. 1992). If only one prevention program was implemented in a community, then changes in behavior can be plausibly attributed to that intervention. However, multicomponent interventions obtain better results.

In most communities, programs directed toward reducing tobacco use among youth have multiple components. One example of this is a project implemented in the Midwest that had the following elements (Johnson et al. 1990):

- A 10-session, school-based, curriculum-driven program teaching resistance skills focused on all forms of drug use (including tobacco)
- Ten homework sessions involving active interviews and role playing with parents and family members
- Mass media coverage, including a total of 16 television, 10 radio, and 30 print media events broadcast over the metropolitan area
- Interventions designed to inform community policy makers about drug abuse issues and to motivate them to lead the community against drug abuse

The principal advantage of a multicomponent approach is that synchronized efforts targeting one problem are likely to be more effective in achieving the desired goals than are uncoordinated, possibly disjointed multiple efforts or single-component efforts addressing the same problem. Potential impediments to implementing multicomponent, community-based approaches to reduce the use of tobacco products by youth, however, include the following:

- First, communities vary greatly in size and diversity. The larger the community, the greater the likelihood of divergent opinions about the nature and extent of the problem of tobacco use by youth, its causes, and its relative importance, all of which need definition to determine what might be seen as the most effective ways to reduce the problem.
- Second, communities, and various segments and organizations within them, have different histories and are at different developmental stages. As noted earlier, in some communities important players in reducing tobacco use among youth may be in the tolerance or denial stage of readiness (see the stages of readiness described above). Others may be at the initiation stage of readiness. This creates difficulty in presenting a unified front in addressing the problem and in securing commitments for collective action.

Therefore, although there is general agreement that multicomponent approaches to reducing tobacco use among youth have the highest possibility of achieving success, ideally all of the key people and organizations dealing with the problem should be ready to take action to address it (Thompson et al. 1991). One important benefit of multicomponent approaches to tobacco control is affirmation of the principle that as many community elements as possible should be involved to obtain sustained changes that will result in new community norms regarding tobacco use (Thompson et al. 1991).

## Summary

Community-based multicomponent approaches are essential elements of effective tobacco control. Through the active involvement of community members and organizations, such approaches are designed to promote synergy among components, change community norms and laws regarding the problem, and provide the community with the skills to address current and future health problems. Such communities can create sustained prevention programs with complementary prevention activities for youth.

Finally, a community process that involves youth in every aspect will perhaps have long-term results. Youth exposed to consistent antitobacco messages in an environment that restricts tobacco use may be less likely to try tobacco products or become addicted to nicotine as adolescents and carry that addiction into adulthood. The next chapter presents various levels of evidence supporting each of the approaches that can be implemented as part of a multicomponent community-based program to prevent tobacco use among youth.

## References

Akers, R. Drugs, Alcohol, and Society: Social Structure, Process, and Policy. Belmont, CA: Wadsworth, 1992.
Altman, D.G.; Rasenick-Douss, L.; Foster, V.; and Tye, J.B. Sustained effects of an educational program to reduce sales of cigarettes to minors. American Journal of Public Health. 1991;81:891-893. [pmid: 2053666].
Altman, D.G.; Linzer, J.; Kropp, R.; Descheemaeker, E.; Feighery, E.; and Fortman, S.P. Policy alternatives for reducing tobacco sales to minors: Results from a national survey of chain and franchise stores. Journal of Public Health Policy. 1992;13:318-331. [pmid: 1401050].
Bal, D.G.; Kizer, K.W.; Felten, P.G.; Mozar, H.N.; and Niemeyer, D. Reducing tobacco consumption in California: Development of a statewide antitobacco use campaign. Journal of the American Medical Association. 1990;264:1570-1574. [pmid: 2395199].
Barovich, M.; Sussman, S.; Dent, C.W.; Burton, D.; and Flay, B.R. Availability of tobacco products at stores located near public schools. International Journal of Addictions. 1991;26:837-850.
Beal, G.M. Social action: Instigated social change in large social systems. In: Copp, J.H., ed. Our Changing Rural Society: Perspectives and Trends. Ames, Iowa: Iowa State University Press, 1964.
Benowitz, N.L. Cigarette smoking and nicotine addiction. Medical Clinics of North America. 1992;76:415-437. [pmid: 1548969].
Best, J.A.; Flay, B.R.; Towson, S.M.J.; Ryan, K.B.; Perry, C.L.; Brown, K.S.; Kersell, M.W.; and D'Averrias, J.R. Smoking prevention and the concept of risk. Journal of Applied Social Psychology. 1984;14:257-273.
Blum, A. The Marlboro Grand Prix: Circumvention of the television ban on tobacco advertising. New England Journal of Medicine. 1991;324:913-917. [pmid: 2000115].
Botvin, G.J.; Goldberg, C.J.; Botvin, E.M.; and Dusenbury, L. Smoking behavior of adolescents exposed to cigarette advertising. Public Health Reports. 1993;108:217-223. [pmid: 8464979].
Brook, J.; Cohen, P.; Whiteman, M.; and Gordon, A. Psycho-social risk factors/Transitions in drug use: Risk and protective factors. In: Glantz, M., and Pickens, R., eds. Vulnerability to Drug Abuse. Washington, DC: American Psychological Association, 1992. pp. 359--388.
Centers for Disease Control and Prevention. Cigarette smoking among youth - United States, 1989. Morbidity and Mortality Weekly Report. 1991;40:712-715. [pmid: 1944119].
Centers for Disease Control and Prevention. Comparison of the cigarette brand preferences of adult and teenage smokers - United States, 1989, and 10 U.S. communities, 1988 and 1990. Morbidity and Mortality Weekly Report. 1992a;41:169-173, 179--181. [pmid: 1538687].
Centers for Disease Control and Prevention. Accessibility of cigarettes to youths aged 12--17 years - United States, 1989. Morbidity and Mortality Weekly Report. 1992b;41:485-488. [pmid: 1614386].
Centers for Disease Control and Prevention. Cigarette smoking - attributable mortality and years of potential life lost - United States, 1990. Morbidity and Mortality Weekly Report. 1993a;42:645-649. [pmid: 8350857].
Centers for Disease Control and Prevention. Minors' access to tobacco - Missouri, 1992, and Texas, 1993. Morbidity and Mortality Weekly Report. 1993b;42:125-128. [pmid: 8437540].
Centers for Disease Control and Prevention. Medical-care expenditures attributable to cigarette-smoking - United States, 1993. Morbidity and Mortality Weekly Report. 1994;43(26):469-472. [pmid: 8007931].
Choi, W.S.; Novotny, T.E.; and Thimis, A.T. Restricting minors' access to tobacco: A review of State legislation, 1991. American Journal of Preventive Medicine. 1992;8:19-22. [pmid: 1575996].
Clayton, R. Transitions in drug use: Risk and protective factors. In: Glantz, M.D., and Pickens, R.W., eds. Vulnerability to Drug Abuse. Washington, DC: American Psychological Association Press, 1992. pp. 15--22.
Clayton, R., and the Ann Arbor Group. Increase in Use of Selected Drugs: Monitoring the Future Study of 8th-, 10th-, and 12th- Graders. Unpublished preliminary final report to the Office of National Drug Control Policy, 1994.
Coalition on Smoking OR Health. Saving Lives and Raising Revenue: The Case for Major Increases in State and Federal Tobacco Taxes. Washington, DC: Coalition on Smoking OR Health, 1993.
Cummings, K.M.; Sciandra, E.; Pechacek, T.F.; Orlandi, M.; and Lynn, W.R. Where teenagers get their cigarettes: A survey of the purchasing habits of 13--16 year olds in 12 U.S. communities. Tobacco Control. 1992;1:264-267.
Davis, R.M., and Jason, L.A. The distribution of free cigarette samples to minors. American Journal of Preventive Medicine. 1988;4:21-26. [pmid: 3395486].
DiFranza, J.R. School tobacco policy: A medical perspective. Journal of School Health. 1989;59:398-400. [pmid: 2607754].
DiFranza, J.R.; Richards, J.W.; Paulman, P.M.; Wolf-Gillespie, N; Fletcher, C.; Jaffe, R.D.; and Murray, D. RJR Nabisco's cartoon camel promotes Camel cigarettes to children. Journal of the American Medical Association. 1991;266:3149-3153. [pmid: 1956102].
Erickson, A.C.; McKenna, J.W.; and Romano, R.M. Past lessons and new uses of the mass media in reducing tobacco consumption. Public Health Reports. 1990;105:239-244. [pmid: 2113681].
Farquhar, J.W.; Fortmann, S.P.; Flora, J.A.; Taylor, B.; Haskell, W.L.; Williams, P.T.; Maccoby, N.; and Wood, P.D. Effects of communitywide education on cardiovascular disease risk factors: The Stanford Five-City Project. Journal of the American Medical Association. 1990;264:359-365. [pmid: 2362332].
Federal Trade Commission. Report to Congress for 1993. U.S. Department of Health and Human Services, Center for Disease Control and Prevention, Office on Smoking and Health, 1995.
Feighery, E.; Altman, D.G.; and Shaffer, G. The effects of combining education and enforcement to reduce tobacco sales to minors: A study of four northern California communities. Journal of the American Medical Association. 1991;266:3168-3171. [pmid: 1956106].
Fischer, P.M.; Schwartz, M.P.; Richards Jr., J.W.; Goldstein, A.O.; and Rojas, T.H. Brand logo recognition by children aged 3 to 6 years: Mickey Mouse and Old Joe the camel. Journal of the American Medical Association. 1991;266:3145-3148. [pmid: 1956101].
Flay, B.R. Selling the Smokeless Society: 56 Evaluated Mass Media Programs and Campaigns Worldwide. Washington, DC: American Public Health Association, 1987.
Flay, B.R.; Koepke, D.; Thompson, S.J.; Santi, S.; Best, A.; and Brown, K.S. Six-year follow-up of the first Waterloo school smoking prevention trial. American Journal of Public Health. 1989;79:1371-1376. [pmid: 2782505].
Flynn, B.S.; Worden, J.K.; Secker-Walker, R.H.; Badger, G.J.; Geller, B.M.; and Costanza, M.C. Prevention of cigarette smoking through mass media intervention and school programs. American Journal of Public Health. 1992;82:827-834. [pmid: 1585963].
Forster, J.L.; Hourigan, M.; and McGovern, P. Availability of cigarettes to underage youth in three communities. Preventive Medicine. 1992;21:320-328. [pmid: 1614994].
Gallup, G., and Newport, F. Many Americans favor restrictions on smoking in public places. Gallup Poll Monthly. 1990;298:19-27.
Gerstein, D., and Green, L. Preventing Drug Abuse: What Do We Know? Washington, DC: National Academy Press, 1993.
Glantz, S.A. Changes in cigarette consumption, prices, and tobacco industry revenues associated with California's Proposition 99. Tobacco Control. 1993;2:311-314.
Green, L.W., and Kreuter, M.W. Health Promotion Planning: An Educational and Environmental Approach. 2nd ed. Mountain View: Mayfield Publishing Company, 1991.
Hansen, W.B. School-based substance abuse prevention: A review of the state of the art in curriculum, 1980--1990. Health Education Research. 1992;7:73-97.
Hawkins, J.D., and Weis, J.G. The social development model: An integrated approach to delinquency prevention. Journal of Primary Prevention. 1985;6:73-97.
Henningfield, J.E.; Clayton, R.R.; and Pollin, W. Involvement of tobacco in alcoholism and illicit drug use. British Journal of Addiction. 1990;85:279-292. [pmid: 2180511].
Henningfield, J.E.; Cohen, C.; and Slade, J.D. Is nicotine more addictive than cocaine?. British Journal of Addiction. 1991;86:565-569. [pmid: 1859920].
Herdman, R.; Hewitt, M.; and Laschober, M. Smoking-Related Deaths and Financial Costs: Office of Technology Assessment Estimates for 1990. Testimony Before the Senate Special Committee on Aging. Hearing on Preventive Health: An Ounce of Prevention Saves a Pound of Cure. May 6, 1993. pp. 2--4.
Hoppock, K.C., and Houston, T.P. Availability of tobacco products to minors. The Journal of Family Practice. 1990;30:174-176. [pmid: 2299312].
Hughes, J., and Hatsukami, D. Signs and symptoms of tobacco withdrawal. Archives of General Psychiatry. 1986;43:289-294. [pmid: 3954551].
Hugick, L., and Leonard, J. Despite increasing hostility, one in four Americans still smokes. Gallup Poll Monthly. 1991;299:10-15.
Institute of Medicine. Growing Up Tobacco Free: Preventing Nicotine Addiction in Children and Youths. Lynch, B.S., and Bonnie, R.J., eds. Washington, DC: National Academy Press, 1994.
Jason, L.A.; Ji, P.Y.; Anes, M.D.; and Birkhead, S.H. Active enforcement of cigarette control laws in the prevention of cigarette sales to minors. Journal of the American Medical Association. 1991;266:3159-3161. [pmid: 1956104].
Jessor, R., and Jessor, S. Problem Behavior and Psychosocial Development. New York: Academic Press, 1977.
Johnson, C.; Pentz, M.; Weber, M.; Dwyer, J.; Baer, N; MacKinnon, D.; Hansen, W.; and Flay, B. Relative effectiveness of comprehensive community programming for drug abuse prevention with high-risk and low-risk adolescents. Journal of Consulting and Clinical Psychology. 1990;58:447-456. [pmid: 2212182].
Johnston, L.; O'Malley, P.; and Bachman, J. National Survey Results on Drug Use from the Monitoring the Future Study, 1975--1993. NIH Pub. No. 94--3809. Washington, DC: Supt. of Docs., U.S. Govt. Print. Off., 1994.
Kessler, D.A. Statement on nicotine-containing cigarettes. Tobacco Control. 1994;3:148-158.
Leventhal, H.; Keeshan, P.; Baker, T.; and Wetter, D. Smoking prevention: Towards a process approach. British Journal of Addiction. 1991;86:583-587. [pmid: 1859923].
Luepker, R.V.; Murray, D.M.; Jacobs, D.R.; Mittelmark, M.B.; Bracht, N.; Carlaw, R.; Crow, R.; Elmer, P.; Finnegan, J.; Folsom, A.R.; Grimm, R.; Hannan, P.J.; Jeffrey, R.; Lando, H.; McGovern, P.; Mullis, R.; Perry, C.L.; Pechacek, T.; Pirie, P.; Sprafka, M.; Weisbrod, R.; and Blackburn, H. Community education for cardiovascular disease prevention: Risk factor changes in the Minnesota health program. American Journal of Public Health. 1994;84:1383-1393. [pmid: 8092360].
Markle, G.E., and Troyer, R.J. Smoke gets in your eyes: Cigarette smoking as deviant behavior. Social Problems. 1979;26:611-625.
McGinnis, J.M., and Foege, W.H. Actual causes of death in the United States. Journal of the American Medical Association. 1993;270:2207-2212. [pmid: 8411605].
McNeill, A.D. The development of dependence on smoking in children. British Journal of Addiction. 1991;86:589-592. [pmid: 1859924].
National Institute on Drug Abuse. National Household Survey on Drug Abuse: Main findings, 1991. DHHS Pub. No. (ADM)90--1682. Washington, DC: Supt. of Docs., U.S. Govt. Print. Off. 1992.
Neuhring, E., and Markle, G.E. Nicotine and norms: The emergence of a deviant behavior. Social Problems. 1974;26:611-625.
Oetting, E.R.; Donnermeyer, J.F.; Plested, B.A.; Edwards, R.W.; Kelly, K.J.; and Beauvais, F. Assessing community readiness for prevention. Colorado State University Tri-ethnic Center for Prevention Research. Unpublished paper, 1994.
Owen, N.; Wakefield, M.; Roberts, L.; and Esterman, A. Stages of readiness to quit smoking: Population prevalence and correlates. Health Psychology. 1992;11:413-417. [pmid: 1286661].
Pentz, M.A.; MacKinnon, D.P.; Dwyer, J.H.; Wang, E.Y.I.; Hansen, W.B.; and Flay, B.R. Longitudinal effects of the midwestern prevention project on regular and experimental smoking in adolescents. Preventive Medicine. 1989a;18:304-321. [pmid: 2740299].
Pentz, M.A.; MacKinnon, D.P.; Flay, B.R.; Hansen, W.B.; Johnson, C.A.; and Dwyer, J.H. Primary prevention of chronic diseases in adolescence: Effects of the midwestern prevention project on tobacco use. American Journal of Epidemiology. 1989b;130:713-724. [pmid: 2788994].
Pentz, M.A.; Brannon, B.R.; Charlin, V.L.; Barrett, E.J.; MacKinnon, D.P.; and Flay, B.R. The power of policy: The relationship of smoking policy to adolescent smoking. American Journal of Public Health. 1989c;79:857-862. [pmid: 2735472].
Perry, C.L.; Kelder, S.H.; Murray, D.M.; and Klepp, K.I. Communitywide smoking prevention: Long-term outcomes of the Minnesota heart health program and the class of 1989 study. American Journal of Public Health. 1992;82:1210-1216. [pmid: 1503159].
Peterson, D.E.; Zeger, S.L.; Remington, P.L.; and Anderson, H.A. The effect of State cigarette tax increases on cigarette sales 1955-1988. American Journal of Public Health. 1992;82:94-96. [pmid: 1536343].
Pierce, J.P.; Gilpin, E.; Burns, D.M.; Whalen, E.; Rosbrook, B.; Shopland, D.; and Johnson, M. Does tobacco advertising target young people to start smoking? Evidence from California. Journal of the American Medical Association. 1991;266:3154-3158. [pmid: 1956103].
Pierce, J.P.; Farkas, A.; Evans, N.; Berry, C.; Chui, W.; Rosbrook, B.; Johnson, M.; and Bal, D.G. Tobacco Use in California: A Focus on Preventing Uptake in Adolescents. Sacramento, CA: California Department of Health Services, 1993. 1991;266:3154-3158.
Prochaska, J.O.; DiClemente, C.C.; and Norcross, J.C. In search of how people change: Applications to addictive behaviors. American Psychologist. 1992;47:1102-1114. [pmid: 1329589].
Puska, P.; Nissinen, A.; Tuomilehto, J.; Salonen, J.T.; Koskela, K.; McAlister, A.; Kottke, T.E.; Maccoby, N.; and Farquhar, J.W. The community based strategy to prevent coronary heart disease: Conclusions from the ten years of the North Karelia Project. Annual Review of Public Health. 1985;6:147-193.
Rogers, E.M. Diffusion of Innovations. 3rd ed. New York: The Free Press, 1983.
Rogers, E.M.; Burdge, R.J.; Korsching, P.F.; and Donnermeyer, J.F. The community based strategy to prevent coronary heart disease: Conclusions from the ten years of the North Karelia Project. Social Change in Rural Societies. 3rd ed. Englewood Cliffs, NJ: Prentice Hall, 1989.
Scheier, L.M., and Newcomb, M.D. Differentiation of early adolescent predictors of drug use versus abuse: A developmental risk factor model. Journal of Substance Abuse. 1991;3:277-299. [pmid: 1821285].
Slade, J. Adolescent nicotine use and dependence. Adolescent Medicine: State of the Art Reviews. 1993;4:305-320.
STAT (Stop Teenage Addiction to Tobacco). Cigarette smoking and sales drop in Massachusetts. Tobacco Free Youth Reporter. Autumn 1994;1(6).
Substance Abuse and Mental Health Services Administration. National Household Survey on Drug Abuse: Population Estimates 1993. DHHS Pub. No. (SMA)94-3017. Rockville, MD: U.S. Department of Health and Human Services, Public Health Service, Substance Abuse and Mental Health Services Administration, 1994.
Thompson, B.; Wallack, L.; Lichtenstein, E.; and Pechacek, T. Principles of community organization and partnership for smoking cessation in the community intervention trial for smoking cessation (COMMIT). International Quarterly of Community Health Education. 1991;11:187-203. [pmid: 20840948].
Troyer, R.J., and Markle, G.E. Cigarettes: The Battle Over Smoking. New Brunswick, NJ: Rutgers University Press, 1983.
U.S. Department of Health and Human Services. The Health Consequences of Smoking: Nicotine Addiction. A Report of the Surgeon General. Atlanta, Georgia: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1988.
U.S. Department of Health and Human Services. Model Sale of Tobacco Products to Minors Control Act. A Model Law Recommended for Adoption for Localities to Prevent the Sale of Tobacco Products to Minors. Washington, DC: Department of Health and Human Services, 1990.
U.S. Department of Health and Human Services. Preventing Tobacco Use Among Young People: A Report of the Surgeion General. Atlanta, Georgia: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1994.
Warren, R. The Community in America. 3rd ed. Chicago: Rand-McNally, 1978.
Wells, B.L. Building inter-community cooperation. Journal of Community Development Society. 1990;21:1-17.
Woodruff, S.I.; Erickson, A.D.; Wildey, M.B.; and Kenney, E.M. Changing retailer knowledge, attitudes, and behaviors related to cigarette sales to minors. Journal of Community Psychology. 1993;21:234-245.