# Resource Guide

This Resource Guide, as its name suggests, provides the reader with specific resources for developing programs to reduce youth tobacco use. The first part lists names and addresses of researchers and practitioners whose work was considered as evidence in evaluating the various intervention programs. Because detailed descriptions of their program planning and content is beyond the scope of this Guideline (and is not fully described in their published works), CSAP thought that those interested in implementing specific strategies may want to obtain more detailed information directly from these researchers and practitioners.

The second part of this appendix lists the various Government and Nongovernment Agencies that maintain repositories of information on youth tobacco use available to the public. While many of these agencies, such as the Bureau of Alcohol, Tobacco, and Firearms of the U.S. Department of Treasury, do not primarily focus on reducing tobacco use among youth, they often have useful data related to incidence, prevalence, consequences of use, licencing, enforcement, or other aspects that practitioners might find useful in developing their educational and program planning strategies.

## Researchers and Practitioners

### Researchers

- David Altman, PhD
- Bauman Gray School of Medicine
- Department of Public Health Services
- Social Sciences and Health Policy
- Medical Center Boulevard
- Winston-Salem, NC 27157

- Karl Bauman, PhD
- Department of Health Behavior and Health Education
- School of Public Health
- University of North Carolina
- 319 Rosenau Hall, #CB7400
- Chapel Hill, NC 27599-7400

- Anthony Biglan, PhD
- Oregon Research Institute
- 1715 Franklin Boulevard
- Eugene, OR 97403

- Christine Edwards, MPH
- Tobacco Control Program Evaluation
- San Diego State University
- 6363 Alvarado Court
- Suite 100
- San Diego, CA 92120

- John Elder, PhD, MPH
- Graduate School of Public Health
- San Diego State University
- 5500 Campanile Drive
- San Diego, CA 92182-4162

- Ellen Feighery, RN, MS
- Center for Research in Disease Prevention
- Stanford University School of Medicine
- 1000 Welch Road
- Palo Alto, CA 94304

- Brian Flay, DPhil
- Prevention Research Center
- School of Public Health
- University of Illinois at Chicago
- 850 West Jackson Boulevard
- Suite 400
- Chicago, IL 60607

- Brian Flynn, ScD
- Office of Health Promotion Research
- One South Prospect
- No. 4427G
- College of Medicine
- University of Vermont
- Burlington, VT 05401

- Jean Forster, PhD, MPH
- Division of Epidemiology
- School of Public Health
- University of Minnesota
- 1300 South Second Street
- Suite 300
- Minneapolis, MN 55454

- Stanton Glantz, PhD
- Institute for Health Policy Studies
- Box 0124
- University of California
- San Francisco, CA 94143-0124

- Ward Hinds, MD, MPH
- Snohomish Health District
- 3020 Rucker Avenue
- Suite 300
- Everett, WA 98201

- Leonard Jason, PhD
- Department of Psychology
- DePaul University
- 2219 North Kenmore
- Chicago, IL 60614

- David MacKinnon, PhD
- Department of Psychology
- Arizona State University
- Tempe, AZ 85287-1104

- Jeffrey McKenna, MS
- Health Communication Branch
- Office on Smoking and Health
- National Center for Chronic Disease Prevention and Health Promotion
- Centers for Disease Control and Prevention
- 4770 Bufford Highway, NE
- Mail Stop K-50
- Atlanta, GA 30341-3724

- David Murray, PhD
- Division of Epidemiology
- School of Public Health
- University of Minnesota
- 1300 South Second Street
- Suite 300
- Minneapolis, MN 55454-1015

- Mary Ann Pentz, PhD
- Norris Comprehensive Cancer Center
- Department of Preventive Medicine
- School of Medicine
- University of Southern California
- 1441 Eastlake Avenue
- MS-44
- Los Angeles, CA 90033-0800

- Cheryl Perry, PhD
- Division of Epidemiology
- School of Public Health
- University of Minnesota
- 1300 South Second Street
- Suite 300
- Minneapolis, MN 55455

- James Popham, EdD
- IOX Assessment Associates
- 5301 Beethoven Street
- Suite 190
- Los Angeles, CA 90066

- Michelle Skretny
- Division of Cancer Control and Epidemiology
- Roswell Park Cancer Institute
- Elm and Carlton Streets
- Buffalo, NY 14263

- Marguerite Stevens, PhD
- Department of Community and
- Family Medicine
- Dartmouth Medical School
- Dartmouth University
- Hinman Box 7927
- Hanover, NH 03755-3861

- Kenneth Warner, PhD
- Department of Health Management and Policy
- School of Public Health
- University of Michigan, Ann Arbor
- Ann Arbor, MI 48109-2029

- Chudley Werch, PhD
- Center for Drug Abuse Prevention and Health Promotion
- College of Health
- University of North Florida
- 4567 St. Johns Bluff Road South
- Jacksonville, FL 32216

- Marianne Wildey, MPH
- Project Middle School,
- Physical Activity, and Nutrition
- 6363 Alvarado Court
- Suite 245
- San Diego, CA 92120

### Practitioners

- Gazelle Babraee
- Health Is Wealth
- Asian Health Services
- 818 Webster Street
- Oakland, CA 94607
- Phone: (510) 986-6800

- Donna Grande
- Project ASSIST
- National Institutes of Health
- National Cancer Institute - DCPC
- 9000 Rockville Pike
- Reducing Tobacco Use Among Youth
- Executive Plaza North, Room 241
- Bethesda, MD 20892
- Phone: (301) 496-0273
- Fax: (301) 496-8675

- Tammy Hopkins
- Tobacco Education Program
- Southwest Utah Mental Health/
- Alcohol and Drug Center
- 354 East 600 South NO 202
- St. George, UT 84770
- Phone: (801) 628-0426
- Fax: (801) 673-7471

- Patricia Jensen
- Stop Teenage Addiction to Tobacco
- Center for Research in Disease Prevention
- Stanford University
- 960 West Headding, Suite 20
- San Jose, CA 95126
- Phone: (408) 247-7828
- Fax: (408) 452-4636

- Rick Kropp
- Stop Tobacco Access for Minors Project
- North Bay Health Resources Center
- 55 Maria Drive
- Suite 837
- Petaluma, CA 94954
- Phone: (707) 762-4591

- Captain Dana S. Mitchell
- Dover Youth Access to Tobacco Reduction Program
- Dover Police Department
- 46 Locust Street
- Dover, NH 03820
- Phone: (603) 742-4646
- Fax: (603) 749-3956

- Janet Porter
- Tobacco-Free Soccer League Initiative Project
- Health Education Council
- 1721 2nd Street, Suite 101
- Sacramento, CA 95814
- Phone: (916) 556-3344

- Todd Tobias
- Say Yes to Sports
- San Diego Hall of Champions
- 1649 El Prado
- San Diego, CA 92101
- Phone: (619) 234-2544
- Fax: (619) 234-4543

- Darryl Whitaker
- Ski Tobacco-Free Project
- Kirkwood Ski Education Foundation
- P.O. Box 161
- Kirkwood, CA 95646
- Phone: (209) 258-5733
- Fax: (209) 258-8370

- Samela Zubow
- Pajaro Valley Prevention and
- Student Assistance
- Pajaro Valley Unified School District
- 18 West Lake Avenue, Suite P
- Watsonville, CA 95076
- Phone: (408) 728-6445
- Fax: (408) 761-6011

## Agencies and Organizations

### Government Agencies

- Agency for Health Care Policy and Research
- Publications Clearinghouse
- 1-800-358-9295
- http://www.ahcpr.gov

- Center for Substance Abuse Prevention
- National Clearinghouse for Alcohol and Drug Information
- (301) 468-2600
- 1-800-Say-No-To
- http://www.health.org

- Centers for Disease Control and Prevention
- National Center for Chronic Disease Prevention and Health Promotion
- Office on Smoking and Health
- (770) 488-5705 (publication requests)
- 1-800-CDC-1311 (media campaign line)
- http://www.cdc.gov/tobacco

- Environmental Protection Agency
- Indoor Air Quality Information Clearinghouse
- (513) 569-7562
- http://www.epa.gov

- Federal Trade Commission
- Public Reference Branch
- (202) 326-2222 (publications)
- (202) 326-3150 (tobacco-related questions)

- Food and Drug Administration
- Office of Consumer Affairs
- (301) 443-3170
- http://www.fda.gov/bbs/tobacinfo/juristoc.html

- Indian Health Service
- Communications Staff
- (301) 443-3593

- National Cancer Institute
- Office of Cancer Communications
- 1-800-4-CANCER
- http://www.nci.nih.gov/occdocs/occ.htm

- National Center for Health Statistics
- Data Dissemination Branch
- (301) 436-8500
- http://www.cdc.gov/nchswww/nchshome.htm

- National Health Information Center
- 1-800-336-4797
- (301) 565-4167
- http://nhic-nt.health.org

- National Heart, Lung, and Blood Institute
- Information Center
- (301) 251-1222

- National Institute for Occupational Safety and Health
- Technical Information Branch
- 1-800-35-NIOSH
- (513) 533-8326
- http://www.cdc.gov/niosh/homepage.html

- National Oral Health Information Clearinghouse
- (301) 402-7364
- nidr@aerie.com

- National Technical Information Service
- (703) 487-4650
- 1-800-553-NTIS

- Occupational Safety and Health Administration
- Department of Labor
- (202) 219-8151
- http://www.osh1a.gov

- Office of Minority Health Resource Center
- (800) 444-6472

- United States Department of Agriculture
- Tobacco and Peanut Division
- (202) 720-4318

- United States Department of Treasury Bureau of Alcohol, Tobacco, and Firearms
- Distilled Spirits and Tobacco Branch
- (202) 927-8210

### Nongovernment Organizations

- Action on Smoking and Health
- (202) 659-4310
- http://ash.org/ash/

- The Advocacy Institute
- (202) 659-8475

- American Association of Retired Persons
- Health Advocacy Service
- (202) 434-2300

- American Cancer Society
- 1-800-ACS-2345
- http://www.cancer.org/tobacco.html

- American Council on Science and Health
- (212) 362-7044

- American Heart Association
- National Center
- 1-800-AHA-USA1
- http://www.amhrt.org

- American Lung Association
- (212) 315-8700
- 1-800-LUNG-USA
- http://www.lungusa.org

- American Medical Association
- (312) 464-5000
- http://www.ama-assn.org

- Americans for Nonsmokers' Rights
- (510) 841-3032
- http://www.no-smoke.org

- Association of State and Territorial Health Officials
- (202) 546-5400

- Coalition on Smoking OR Health
- (202) 452-1184

- Doctors Ought to Care
- (713) 528-1487
- http://www.bcm.tmc.edu/doc

- Group Against Smokers' Pollution
- (301) 459-4791

- March of Dimes Birth Defects Foundation
- (914) 428-7100

- National Federation TARGET Program
- (816) 464-5400

- SmokeFree Educational Services, Inc.
- (212) 912-0960

- Stop Teenage Addiction to Tobacco
- (413) 732-STAT