# Collateral Research

Presented here are citations of selected research involving related substance abuse areas and populations. Further information about the effectiveness of some approaches discussed in this guideline may be derived from these publications.

## General

Cassady, D.; Flora, J.; and Foote, D. Increasing Community Involvement in Alcohol Licensing: How to Work with the Alcohol Beverage Control (ABC). County of San Diego, California Department of Health Services, 1987.
Casswell, S., and Lynette, G. An evaluation community action project on alcohol. Journal of Studies on Alcohol. 1989;50:339-346. [pmid: 2755135].
Farquhar, J.W.; Fortmann, S.P.; Flora, J.A.; Taylor, B.; Haskell, W.L.; Williams, P.T.; Maccoby, N.; and Wood, P.D. Effects of communitywide education on cardiovascular disease risk factors: The Stanford Five-City Project. Journal of the American Medical Association. 1990;264:359-365. [pmid: 2362332].
Gruenewald, P.; Madden; and Janes, K. Alcohol availability and the formal power and resources of State alcoholic beverage control agencies. Alcoholism: Clinical and Experimental Research. 1992;16:591-597.
Hennessy, M. Designing and evaluating alcohol problem community interventions: Quasi-lessons from the experience of medical trials. Journal of Primary Prevention. 1991;11:169-192.
Holder, H.D. Community prevention: A systems perspective for alcohol abuse. Psychiatric Annals. 1984;14:589-594.
Holder, H.D. "Prevention of Alcohol-involved Traffic Crashes: Research Implications of Alcohol Access, Price, and Mass Communications." Conference Paper, Irvine, CA, July 27--29, 1992.
Mooney, L. The differential effects of the minimum drinking age law. Sociological Inquiry. 1993;63:331-338.
Mosher, J.F., and Jernigan, D.H. Public action and awareness to reduce alcohol-related problems: A plan of action. Journal of Public Health Policy. 1988;9:17-41. [pmid: 3360913].
Office of the Surgeon General. Surgeon General's Workshop on Drunk Driving: Selected Recommendations Made to the Surgeon General by the Expert Panels for Nine Action Groups: December 14 to 16, 1988, Washington, D.C. Rockville, MD: U.S. Department of Health and Human Services, Public Health Service, Office of the Surgeon General, 1988.
O'Malley, P., and Wagenaar, A.C. Effects of minimum drinking age laws on alcohol use, related behaviors and traffic crash involvement among American youth: 1976--1987. Journal of Studies on Alcohol. 1991;52:478-491. [pmid: 1943105].
Pentz, M.A.; Dwyer, J.H.; MacKinnon, D.P.; Flay, B.R.; Hansen, W.B.; Wang, E.Y.I.; and Johnson, C.A. A multicommunity trial for primary prevention of adolescent drug abuse: Effects on drug use prevalence. Journal of the American Medical Association. 1989;261:3259-3266. [pmid: 2785610].
Pentz, M.A. Local policy change as a prevention strategy: Proposal research methods. In: Bukoski, W.J., and Amsel, Z., eds. Drug Abuse Prevention: Sourcebook on Strategies and Research. Westport, CT: Greenwood Publishing, in press.
Puska, P.; Nissinen, A.; Tuomilehto, J.; Salonen, J.T.; Koskela, K.; McAlister, A.; Kottke, T.E.; Maccoby, N.; and Farquhar, J.W. The community-based strategy to prevent coronary heart disease: Conclusions from the ten years of the North Karelia Project. Annual Review of Public Health. 1985;6:147-193.
Thompson, B.; Wallack, L.; Lichtenstein, E.; and Pechacek, T. Principles of community organization and partnership for smoking cessation in the community intervention trial for smoking cessation (COMMIT). International Quarterly of Community Health Education. 1991;11:187-203. [pmid: 20840948].
Wagenaar, A.C. Preventing highway crashes by raising the legal minimum age for drinking: The Michigan experience 6 years later. Journal of Safety Research. 1986;17:101-109.
Wagenaar, A.C., and Perry, C.L. Community strategies for the reduction of youth drinking: Theory and application. Journal of Research on Adolescence. 1994;4:319-345.
Wallack, L. A community approach to the prevention of alcohol-related problems: The San Francisco experience. International Quarterly of Community Health Education. 1985;5:85-102. [pmid: 20841132].

## Economic Interventions

Coate, D., and Grossman, M. Effects of alcoholic beverage prices and legal drinking age on youth alcohol use. Journal of Law and Economics. 1988;31:145-171.
Speiglman, R., and Sawyer, J. "Effects of Environment: Economic and Policy Factors, Alcohol Consumption, and Alcohol-related Problems." First Conference of the Collaborative Alcohol-related Longitudinal Project, Berkeley, CA, July 1987.

## Counteradvertising

Engs, R.C. Is "just say no" a no-go?. Wines and Vines. 1992;73.
Fenaughty, A., and MacKinnon, D. Immediate effects of the Arizona alcohol warning poster. Journal of Public Policy and Marketing. 1993;12:69-77.

## Alcohol Retailer-Directed Interventions

Addiction program seeks to reward responsible sellers of alcohol. Alcoholism and Drug Abuse Weekly 5:4, 1993.
Cassady, D.; Flora, J.; and Foote, D. Server Intervention: Encouraging Responsible Alcoholic Beverage Sales and Service. County of San Diego, California Department of Health Services, 1987.
Delewski, C., and Saltz, R.F. A community action approach to server intervention in two California counties. Contemporary Drug Problems. 1990;17:345-368.
Ditman, D.L. Controlling alcohol availability to youth: A survey of alcohol sales establishments. Sociology Practice Review. 1991;2:281-286.
Dull, T., and Giacopassi, D.J. An assessment of the effects of alcohol ordinances on selected behaviors and conditions. Journal of Drug Issues. 1986;16:511-521.
Dull, T., and Giacopassi, D.J. Dry, damp, and wet: Correlates and presumed consequences of local alcohol ordinances. American Journal of Drug & Alcohol Abuse. 1988;14:499-514. [pmid: 3068984].
Forster, J.L.; McGovern, P.G.; Wagenaar, A.C.; Wolfson, M.; Perry, C.L.; and Anstine, P.S. The ability of young people to purchase alcohol without age identification in northeastern Minnesota, USA. Addiction. 1994.;86:699-705. [pmid: 8069171].
Holder, H.D., and Wagenaar, A.C. Mandated server training and reduced alcohol-involved traffic crashes: A time series analysis of the Oregon experience. Accident Analysis and Prevention. 1994;26:89-97. [pmid: 8110360].
McKnight, A.J. Factors influencing the effectiveness of server-intervention education. Journal of the Study of Alcohol. 1991;52:389-397.
McKnight, A.J. Server intervention: Accomplishments and needs. Alcohol Health and Research World. 1993;17.
Preusser, D.F., and Williams, A.F. Sales of alcohol to underage purchasers in three New York counties and Washington, D.C. Journal of Public Health Policy. 1992;13:306-317. [pmid: 1401049].
[no author listed]. Save Lives: Report and Recommendations of the Join Together Public Policy Panel on Underage Access to Alcohol. Boston, MA: Join Together, 1993.
Single, E. Server intervention: A new approach to the prevention of impaired driving. Health Education Research. 1990;5:237-245.
Wagenaar, A.C.; Finnegan, J.R.; Wolfson, M.; Anstine, P.S.; Williams, C.L.; and Perry, C.L. "Youth Alcohol Access: Where and How Adolescents Obtain Alcoholic Beverages." Presentation at the 18th Annual Alcohol Epidemiology Symposium of the Kettil Bruun Society for Social and Epidemiological Research on Alcohol, Toronto, Canada. University of Minnesota, School of Public Health, Minneapolis, MN, June 1--5, 1992.
Wagenaar, A.C., and Wolfson, M. Enforcement of the minimum legal drinking age in the United States. Journal of Public Health Policy. 1994;15:37-53. [pmid: 8027360].
Wittman, F.D. Planning and programming server intervention initiatives for fraternities and sororities: Experience at a large university. Journal of Primary Prevention. 1989;9:247-269.

## Multicomponent School-Linked Community Approaches

Moskowitz, J.M., and Jones, R. Alcohol and drug problems in the schools: Results of a national survey of school administrators. Journal of Studies on Alcohol. 1988;49:229-305.

## Tobacco-Free Environment Policies

Rigotti, N.A. Trends in the adoption of smoking restrictions in public places and worksites. New York State Journal of Medicine. 1989;89:19-26. [pmid: 2646555].
Woodruff, T.J., Rosbrook, B.; Pierce, J.; and Glantz, S.A. Lower levels of cigarette consumption found in smoke-free workplaces in California. Archives of Internal Medicine. 1993;153:1485-1493. [pmid: 8512439].

## Restriction of Advertising and Promotion

Gerbner, G. Stories that hurt: Tobacco, alcohol, and other drugs in mass media. In: Youth and Drugs: Society's Mixed Messages. OSAP Prevention Monograph No. 6. Resnick, H., ed. DHHS Pub. No. (ADM)90--1689. U.S. Department of Health and Human Services, Public Health Service, Alcohol, Drug Abuse, and Mental Health Administration, Office for Substance Abuse Prevention, 1990. pp. 53--127.
Hilton, M.E., and Kaskutas, L. Public support for warning labels on alcoholic beverage containers. British Journal of Addiction. 1991;86:1323-1333. [pmid: 1751848].
Warner, K.E.; Butler, J.; Cummings, K.M.; D'Onofrio, C.; Davis, R.M.; Flay, B.; McKinney, M.; Myers, M.L.; Pertschuk, M.; Robinson, R.G.; Ryden, L.; Schudson, M.; Tye, J.; and Wilkenfeld, J. Report of the tobacco policy research and study group on tobacco marketing and promotion. Tobacco Control. 1992;1 (Suppl. 1):19-23.