# Methodology for Arriving at Recommendations

## Analysis of Research and Practice Evidence

The analysis of research and practice evidence was conducted on two levels. First, each research study and practice case was analyzed with regard to design strengths, weaknesses, and potential biases. Second, each group of research articles and/or practice cases was analyzed by each approach.

### Individual Level Analysis

Each research study and practice case was analyzed with regard to overall summary information, intervention factors, and research design. Also, practice evidence was analyzed in terms of process evaluation. The format for analyzing research studies and practice cases, the annotation key, is shown in Exhibit C-1.

EXHIBIT C-1: Annotation Shell

(Citation) SECTION 1: SUMMARY OVERVIEW HYPOTHESIS CONCEPTUAL FRAMEWORK PURPOSE OBJECTIVES FINDINGS CONCLUSIONS SECTION 2: THE INTERVENTION TYPE OF INTERVENTION DRUGS OF ABUSE ATOD-RELATED BEHAVIORS GENERAL RISK FACTORS TARGET ENVIRONMENT OR POPULATION SOCIAL OR INSTITUTIONAL SYSTEMS INVOLVED STRATEGIES ACTIVITIES SECTION 3: PROCESS EVALUATION NUMBER OF PERSONS OR AGENCIES SERVED SOCIODEMOGRAPHIC INFORMATION AMOUNT OF SERVICE PROVIDED NUMBER OF MATERIALS DISTRIBUTED AND CALLS RECEIVED LIST OF COLLABORATORS WORK PLANS AND PROGRESS REPORTS NEEDS ASSESSMENT TARGET GROUP REPRESENTATION IN PROGRAM FACILITATION OF OBJECTIVES BY ACTIVITIES APPROPRIATENESS OF MATERIALS RECIPIENT PARTICIPATION AS EXPECTED SECTION 4: RESEARCH DESIGN EVALUATION OR STUDY DESIGN MEASUREMENT ANALYSES ASSESSMENT OF EVIDENCE AUTHOR DISCUSSION OF BIAS COMMENTS

Summary information included an overview of the evidence, the stated or assumed implied hypothesis guiding the intervention, and a description of the conceptual framework, if any. The summary included the purpose of or rationale for the study and the objectives of the intervention. The findings were described, including primary and secondary study outcomes and unintended outcomes, if any.

A substantial amount of information was collected for each intervention. This included the type of intervention; the drugs of abuse, drug-related behaviors, and individual and environmental risk factors being studied; the target population; the social or institutional systems involved; the type of approaches being used; and the specific approaches and activities of the intervention.

The evaluation of the research design was comprehensive and included noting the specific research design employed, the specific behaviors or changes being measured, and statistical analyses used. The process included a comprehensive review of biases that might have influenced the outcomes and attribution of effect.

Each prevention practice case was evaluated with regard to process. The adequacy of quantitative and qualitative information collected was assessed.

### Group Level Analysis (Overall Level of Evidence)

Once research and practice evidence was analyzed on an individual level, the practice cases were analyzed according to prevention approach. The goal of this analysis was to determine what conclusions could be drawn about the evidence within a prevention approach and ascertain the strength of the evidence supporting the conclusions as strong, medium, suggestive but insufficient evidence, or substantial evidence of ineffectiveness. These levels are summarized in Table C-1.

TABLE C-1: Criteria for Grading Levels of Evidence

Level of Evidence | Criteria
1. Strong | a. Consistent positive results of strong or medium positive effect from a series of studies, including at least three well-executed studies with experimental or quasi-experimental designs; determination of this level is strengthened by evidence from research in which at least two different methodologies were used OR Evidence from two well-executed research studies with experimental or quasi-experimental designs and consistent results from at least three case studies; b. Unambiguous time ordering of intervention and results; c. Existence of a plausible conceptual model, ruling out or controlling for alternative causal paths or explanations
2. Medium | a. Consistent positive results from a series of studies, including at least two well-executed studies with experimental or quasi-experimental designs; determination of this level is strengthened by evidence from research in which at least two different methodologies were used OR At least one well-executed study and three case studies showing statistically significant or qualitatively clear effects; b. Unambiguous time ordering of intervention and results, when measured; c. Existence of a plausible conceptual model, whether or not competing explanations have been ruled out
3. Suggestive but insufficient evidence | a. Based on plausible conceptual model or previous research; b. Rigorous evaluation studies or appropriate intervention programs are in process; c. Minimal available evidence linking intervention being tested to positive effect
4. Substantial evidence of ineffectiveness | The absence of a statistically significant effect or evidence of a statistically significant negative effect in a majority of well-executed studies, including at least two quantitative studies with sample sizes sufficient to test for the significance of the effect

## Criteria for Determining Level of Evidence

The criteria for strong level of evidence were consistent positive results of strong or medium effect from at least three well-executed studies with experimental or quasi-experimental designs. Alternatively, two well-executed research studies with experimental or quasi-experimental designs and consistent results from at least three case studies were accepted.

Either way, the use of at least two methodologies, unambiguous time ordering of the intervention and its results, and a plausible conceptual model ruling out or controlling for alternative causal paths or explanations were required.

The criteria for medium level of evidence were consistent positive results from a series of studies, including at least two well-executed studies with experimental or quasi-experimental designs. Alternatively, there can be at least one well-executed study and three prevention case studies showing statistically significant or qualitatively clear effects.

Either way, there should be the use of at least two different methodologies, unambiguous time-ordering of intervention and results when so measured, and a plausible conceptual model, whether or not competing explanations have been ruled out.

A third category, suggestive but insufficient evidence, was used to describe research and/or practice evidence that was based on a plausible conceptual model or on previous research and was being demonstrated in rigorous evaluation studies or appropriate intervention programs. One of two conditions typically prompted this categorization. In the first condition, the evidence, although limited, appeared to support a conclusion, but additional research was needed to fully support this conclusion. This condition often applies to areas in which there has been little study, such as those that are impractical to research or are new. The second condition involves equivocal results: a specific conclusion is supported in some studies but is not supported in others.

The three categories described above provide a way to arrange research and practice evidence for which there are varying degrees of confirmation of positive effect. A fourth category, substantial evidence of ineffectiveness, describes research and practice evidence demonstrating that a prevention approach is not effective. The criterion for inclusion in this category is the absence of a statistically significant effect or evidence of a statistically significant negative effect in a majority of well-executed studies, including at least two quantitative studies with sample sizes sufficient to test for the significance of the effect.

## Rules of Evidence Abstract

In 1992 the Center for Substance Abuse Prevention (CSAP) created the Prevention Enhancement Protocols System (PEPS) as a part of its initiative to support and strengthen the prevention systems in the States and Territories. PEPS aims to compile, analyze, and synthesize existing knowledge on topics in the prevention of alcohol, tobacco, and other drug (ATOD) problems. These topics are chosen to represent those considered by the field to have major consequences and for which there is substantial knowledge available to synthesize in the form of specific guidelines. The PEPS guidelines are designed to assist States, practitioners, and community-based organizations in planning programs, allocating resources, and choosing program options that are appropriate for the needs of their target populations.

CSAP - as well as other Federal, State, and community-based organizations - has made several previous attempts to provide guidance to the field. PEPS, however, is the first known systematic guideline development process in the field of substance abuse prevention. Although the accumulated knowledge and practice in the field of prevention in general and substance abuse prevention in particular present special challenges for developing systematic guidelines, PEPS has benefited from earlier efforts by Federal agencies and professional medical societies in developing guidelines for medical practice.

Early in the PEPS program, CSAP was faced with the choice of developing guidelines through primary reliance on professional consensus or on explicit evidence. Under the former methodology, a group of well-known consultants is assembled and asked to develop the guidelines based on their knowledge of the literature and their own experience. Under the latter methodology, published and unpublished evidence on a given guideline topic is researched according to a defined protocol and analyzed for validity. The accumulated evidence is then synthesized and its strength assessed according to clearly defined rules before recommendations are developed.

Although the evidence-based approach demands greater effort and investment of resources, CSAP decided that developing the guidelines on the basis of explicit evidence would provide more valid tools for prevention planners and practitioners and would also further the quest for new knowledge in areas where evidence is weak or lacking. To this end, the PEPS Planning Manual was developed to instruct the participants in the various stages of the development of guidelines under the PEPS program.

The planning manual contains a rules of evidence document, that provides criteria for assessing the strength of available evidence on the effectiveness of ATOD problem prevention interventions, measures, and programs. The application of the presented criteria is used by PEPS as the basis for decisions about the level of evidence available about a particular intervention. The level of evidence indicates the level of confidence that there is a causal relationship between a prevention intervention and a change in the outcome(s) of interest and the overall effectiveness of the prevention activity.

The planning manual also presents definitions of research and practice evidence. These definitions are followed by summaries of methodological and design issues to be considered in assessing studies and programs, criteria for determining the strength of evidence for the effectiveness of an intervention, combining research and practice evidence, and procedures for specifying the conditions under which the relationship between an intervention and an outcome operates. The strength or level of evidence for an intervention and the conditions under which this level operates serve as recommendations for applying this intervention to the field.

The assessment criteria and levels of evidence discussed in this appendix were developed for use in the evaluation of existing research and practice evidence. They were not intended for use in designing interventions or research studies or for developing policy.

Table C-1 shows the criteria used by PEPS for grading available research and practice evidence for an ATOD problem prevention intervention to determine a level of evidence regarding its effectiveness.

## Assessment of the Evidence

### Biases

Biases are sources of systematic errors that arise from faulty design, poor data collection procedures, or inadequate analysis. These errors diminish the likelihood that an observed outcome is attributable to the intervention. Biases are inherent in many nonexperimental observational studies but are of special significance in case-control-led studies. Experimental and quasi-experimental study designs control for one or more of these biases.

Selection Bias. A selection bias results when certain individuals are, knowingly or unknowingly, selectively included or excluded from the case or the control group. The systematic and disproportionate frequency of important variables in the cases or the controls may result in a spurious measure of association. Epidemiological studies are laden with potential selection biases, including selective admission, selective nonparticipation, selective survival, and selective detection. An example of selection bias is when a comparison group is not equivalent to the intervention group because of demographic, psychosocial, or behavioral characteristics.

Case-control-led studies are especially susceptible to selection bias. Thus, multiple control groups should be chosen instead of only one, and at least one of the groups should come from the same source of care as the case group.

Measurement Bias. Measurement bias may result when the information collected on either the exposure variable or the health state is unreliable or invalid. Historical data obtained by interviewing subjects but without appropriate validation against recorded data or interviews with collateral sources are especially susceptible to one form of information bias, called recall bias. Another common type of measurement bias is the use of scales that have not been tested for reliability or validity. Ways to control for information bias include using only accurately recorded data, validating interview information, blinding the investigator to the identity of the case or the controls, and adhering to an explicit, standardized method of data collection.

- Confounding bias - An observed effect between intervention A and outcome B may actually be attributable to a third factor, C, which is related to both A and B. In other words, the relationship between A and B is weak or nonexistent, and the explanatory relationship is between C and A or C and B. Thus, an effect can be detected that is attributable to a confounding factor, not to the intervention or policy. Age, ethnicity, sex, and socioeconomic status are important confounders. Ways to control for confounding bias include matching techniques in the design stage and using stratification and multivariate analysis during the analysis stage.
- Attrition - Attrition that is nonrandom or excessive (defined as a dropout rate of 10 percent or more) in the intervention or the control group can introduce a bias in the outcome data. A differential between the groups' dropout rates may also introduce a bias in outcome data.

### Internal Validity

Internal validity is the extent to which an observed effect can be attributed to an intervention. Threats to internal validity are particularly germane to intervention studies, although policy and nonintervention studies may be susceptible to threats relating to statistical power, history, and unit of assignment.

The overall issue regarding internal validity is whether the intervention or some other factor(s) produced the observed effect:

- Equivalence - For studies that have an intervention group and a control or comparison group, comparisons between the two groups are most valid when they consist of subjects that are essentially similar at the beginning of the study. When this is not true, outcomes observed may not be attributable to the intervention because the groups were already different in some way.
- Statistical Power - To detect statistically significant differences in outcomes, there should be an adequate number of participants in each of the intervention and control or comparison groups. The minimum number of participants in each group should be about 30. Having fewer than 30 participants per group generally yields inadequate statistical power. Regardless of the total number in a group, the groups should be about the same size.
- Intervention Contamination - It is important for the control or comparison group to remain unaffected by the intervention. For example, if the control or comparison group were to receive information about the intervention and apply it to themselves, this might obscure the effects of the intervention.
- Randomization or Blinding of Observers - When research study staff know the status of an individual or a group in a study (intervention or control status), they may change their own behavior in ways that can affect the study outcome. To minimize the chance of this bias, the observers can be either blinded to the conditions or randomly assigned to measure either intervention or comparison groups.
- Fidelity - The intervention should be delivered consistently during the intervention period. Ideally, the researchers will have used a written protocol for the intervention delivery and will have documented a standard delivery to all study participants.
- Unit of Analysis and Unit of Assignment - Participants in a prevention program can be assigned to control or intervention status on an individual basis or on a collective basis, such as a classroom or a community. Similarly, the analysis of a research study can be done individually or collectively. The unit of assignment and the unit of analysis should be the same when researchers analyze the effects of the intervention.
- History - A significant and unplanned national, State, local, or internal organizational event or exposure at the program site during the study evaluation period can result in a change by participants. In studies with a time series design, history is the principal threat to internal validity. For these studies, it is particularly important to assess the plausibility of effects of factors such as weather, the seasonality, shifts in personnel, changes in resources, or the enactment of a new law or policy.
- Program or Participant Maturation - Natural, biological, social, behavioral, or administrative changes among the participants or staff members during the study period may result in program or participant maturation and could partially account for the results obtained. Such changes include growing older, becoming more skilled, or for staff, becoming more effective and efficient in program delivery.
- Testing or Observation - Participants' behavior regarding study outcomes can change when they are tested or observed frequently. Measurements made too frequently can themselves change the behavior and responses of study participants. The behavior of study subjects can change simply because, for example, they are taking a test or being interviewed or observed.
- Statistical Regression - Statistical regression can result when an intervention or comparison group is selected on the basis of an unusually high or low level of a characteristic that may change naturally in subsequent measurements. The extent to which regression compromises results can be determined by examining the comparability of people who participate and those who do not. Controlling for statistical regression is difficult in studies employing a one-group pretest and posttest design or a nonequivalent control group.
- Interactive Effects - Any combination of the preceding factors constitutes interactive effects.

### External Validity

The focus of external validity is generalizability, that is, the extent to which an observed effect that is attributable to an intervention can be expected in other settings and populations with similar or different characteristics:

- Contextual Factors - In the ATOD abuse prevention field, contextual factors relates to the degree to which a community is ready to prevent ATOD use. Indicators of community readiness include favorable attitudes, norms, and restrictive policies. Results of studies of communities with a high degree of readiness for prevention may not be generalizable to all communities. For example, the ability to establish outdoor tobacco advertising restrictions would differ between California and North Carolina.
- Generalizability - Factors unique to a study make it difficult to generalize the findings to similar or general populations. For instance, a school-based intervention in a primarily urban setting for African American students may not be generalizable to a suburban school setting with primarily refugee students.

## Bibliography

Campbell, D., and Stanley, J. Experimental and Quasi-experimental Designs for Research. Chicago: Rand McNally, 1966.
Depression Guideline Panel. Depression in Primary Care. Vol. 1, Diagnosis and Detection. Clinical Practice Guideline, No. 5., AHCPR Pub. No. 93--0550. Rockville, MD: U.S. Department of Health and Human Services, Public Health Service, Agency for Health Care Policy and Research, April 1993.
Green, L.W., and Kreuter, M.W. Health Promotion Planning: An Educational and Environmental Approach. Mountain View, CA: Mayfield Publishing, 1991.
Hayward, R.S.; Steinberg, E.P.; Ford, D.E.; Roizen, M.F.; and Roach, K.W. Annals of Internal Medicine.
Hill, A.B. Principles of Medical Statistics. 9th ed. New York: Oxford University Press, 1971, pp. 309--323.
Kleinbaum, D.G.; Kupper, L.L.; and Morgenstern, H. Epidemiological Research: Principles and Quantitative Methods. Belmont, CA: Lifetime Learning Publications, 1982.
Koepsell, T.D.; Wagner, E.H.; Cheadle, A.C.; Patrick, D.L.; Martin, D.C.; Diehr, P.H.; Perrin, E.B.; Kristal, A.R.; Allan-Andrilla, C.H.; and Dey, L.J. Selected methodological issues in evaluating community-based health promotion and disease prevention programs. Annual Review of Public Health. 1992.;13:31-57.
Windsor, R.A.; Baranowski, T.; Clark, N.; and Cutter, G. Evaluation of Health Promotion and Education Programs. Mountain View, CA: Mayfield Publishing, 1984.