# PEPS Participants

PEPS Planning Group
- Richard R. Clayton, Chair
- Center for Prevention Research
- University of Kentucky
- Lexington, KY
- Thomas E. Backer
- Human Interaction Research Institute
- Los Angeles, CA
- Leonard G. Epstein
- Division of Community Prevention and Training
- Center for Substance Abuse Prevention
- Rockville, MD
- Bettye Ward Fletcher
- Research and Development
- Jackson State University
- Jackson, MS
- Jean L. Forster
- Division of Epidemiology
- University of Minnesota School of Public Health
- Minneapolis, MN
- William M. Harvey
- Missouri Institute of Mental Health
- St. Louis, MO
- Ralph W. Hingson
- Social and Behavioral Sciences Department
- Boston University
- Boston, MA
- Jan Howard
- Prevention Research Branch
- National Institute on Alcohol Abuse and Alcoholism
- Rockville, MD
- Ford H. Kuramoto
- Los Angeles Office of National Asian Pacific American Families Against Substance Abuse, Inc.
- Ford H. Kuramoto and Associates
- Monterey Park, CA
- Jeffrey N. Kushner
- Office of Alcohol and Drug Abuse Programs
- Oregon Department of Human Resources
- Salem, OR
- Gloria Martin-Payne
- Pennsylvania Office of Drug and Alcohol Programs
- Harrisburg, PA
- Andrea L. Mitchell
- Alcohol Research Group
- Western Consortium for Public Health
- Berkeley, CA
- Abdin Noboa
- Innovative Consultants International
- Columbus, OH
- Pamela Petersen-Baston
- Independent Consultant
- Key West, FL
- Eva L. Petoskey
- First American Prevention Center
- Suttons Bay, MI
- Robert I. Reynolds
- National Center for the Advancement of Prevention
- Rockville, MD
- Robert G. Robinson
- Office on Smoking and Health
- National Center for Chronic Disease Prevention and Health Promotion
- Centers for Disease Control and Prevention
- Atlanta, GA
- Robin G.W. Room
- The Addiction Research Foundation
- Toronto, ON
- Zili Sloboda
- Division of Epidemiology and Prevention Research
- National Institute on Drug Abuse
- Rockville, MD
- José Szapocznik
- Department of Psychiatry
- Center for Family Studies
- University of Miami School of Medicine
- Miami, FL
- Ralph E. Tarter
- Western Psychiatric Institute and Clinic
- Department of Psychiatry and Neurology
- University of Pittsburgh School of Medicine
- Pittsburgh, PA
- Mel Tremper
- National Center for the Advancement of Prevention
- Rockville, MD
- Friedner D. Wittman
- CLEW Associates
- Berkeley, CA

Ex Officio
- Prakash L. Grover
- Division of State and Community Systems Development
- Center for Substance Abuse Prevention
- Rockville, MD

PEPS Tobacco Federal Resource Panel
- Cynthia Bailey
- Office of Disease Prevention and Health Promotion
- National Health Service
- Washington, DC
- Bill Bukoski
- Prevention Research Branch
- Office of Extramural Program Review
- National Institute on Drug Abuse
- Rockville, MD
- Michele Chang
- Office on Smoking and Health
- National Center for Chronic Disease Prevention and Health Promotion
- Centers for Disease Control and Prevention
- Atlanta, GA
- Donald Coleman
- Office of the Director
- Bureau of Primary Health Care
- Bethesda, MD
- Andrea Edmond
- Housing and Urban Development
- Silver Spring, MD
- Walt Francis
- Office of the Assistant Secretary for Planning and Evaluation
- Public Health Service
- Department of Health and Human Services
- Washington, DC
- Charlotte Gillespie
- Safe and Drug Free Schools Program
- Office of Elementary and Secondary Education
- Department of Education
- Washington, DC
- Elmer Huerta
- Cancer Risk Assessment and Screening Center
- Washington Hospital Center
- Washington, DC
- James Kavanaugh
- National Institute on Child Health and Human Development
- National Institutes of Health
- Bethesda, MD
- Marc Manley
- Public Health Applications Branch
- National Cancer Institute
- Bethesda, MD
- Winnie Mitchell
- Office of the Administrator
- Substance Abuse and Mental Health Services Administration
- Rockville, MD
- John Molnar
- Social Security Office of Inspector General
- New York, NY
- Cliff Mullen
- Wine, Beer, and Spirits Regulation Branch
- Bureau of Alcohol, Tobacco, and Firearms
- Washington, DC
- Alex Ross
- Office of the Assistant Secretary for Health
- Public Health Service
- Department of Health and Human Services
- Washington, DC
- Robert Vollinger
- Division of Communication Programs
- Center for Substance Abuse Prevention
- Rockville, MD
- Barbara Wagner
- Office of the Administrator
- Substance Abuse and Mental Health Services Administration
- Rockville, MD

PEPS Tobacco Expert Panel
- Jean Forster, Chair
- Division of Epidemiology
- University of Minnesota School of Public Health
- Minneapolis, MN
- Nancy Bagnato
- Tobacco Control Section
- California Department of Health Services
- Sacramento, CA
- Tony Biglan
- Oregon Research Institute
- Eugene, OR
- Christine Chalkley
- Statewide Risk Reduction
- Utah Department of Health
- Salt Lake City, UT
- Richard Clayton
- Center for Prevention Research
- University of Kentucky
- Lexington, KY
- Renato Espinoza
- Director
- Center for Minority Health Initiatives
- Texas Department of Health
- Austin, TX
- Ellen Feighery
- Center for Research in Disease Prevention
- Stanford University School of Medicine
- Palo Alto, CA
- Ralph Hingson
- Social and Behavioral Sciences Department
- Boston University
- Boston, MA
- Mary Hourigan
- ASSIST
- Minnesota Department of Health
- Minneapolis, MN
- James Kooler
- California Department of Alcohol and Drug Programs
- Sacramento, CA
- Marilyn Massey
- MasiMax Resources
- James Neal
- South Carolina Department of Alcohol and Other Drug Abuse Services
- Columbia, SC
- Mary Ann Pentz
- Institute for Prevention Research
- University of Southern California
- Los Angeles, CA
- Robert G. Robinson
- Office on Smoking and Health
- National Center for Chronic Disease Prevention and Health Promotion
- Centers for Disease Control and Prevention
- Atlanta, GA
- Randy Schwartz
- Health Promotion and Education
- Bureau of Health
- Augusta, ME

CSAP Representatives
- Prakash L. Grover
- Division of State and Community Systems Development
- Center for Substance Abuse Prevention
- Rockville, MD
- Gale A. Held
- Division of State and Community Systems Development
- Center for Substance Abuse Prevention
- Rockville, MD

Birch & Davis Associates, Inc., Staff
- Jeffery A. Hunter
- Deputy Project Director
- CSAP Prevention Technical Assistance to the States (PTAS)
- Robert Bozzo
- Mary V. Davis (4/94 through 11/96)
- PEPS Project Manager
- Mim J. Landry
- Medical Writer and Research Associate
- William H. Moore
- Jennie E. Heard (through 4/95)
- Deborah J. Shuman (3/95 through 10/96)
- Managing Editors
- Betsy Earp
- Associate Editor (9/95 through 4/96)
- Christine H. Kelley
- Suzanne M. Boland (through 3/95)
- Elizabeth B. Hayes (12/93 through 12/95)
- Research & Editorial Assistants