# Appendices

Appendix A PEPS Participants

Appendix B Research and Practice Search Protocols

Appendix C Methodology for Arriving at Recommendations

Appendix D Collateral Research

Appendix E Abbreviations and Glossary

Appendix F Resource Guide