# Introduction

A major focus throughout our society is the importance of the family in sustaining the foundations of American values; cultures; and religious, educational, economic, and community institutions. Increasingly, however, there are significant indications that our Nation's children are having difficulty acquiring the skills necessary to become competent, caring adults who can live together peacefully and productively in communities. In the face of tremendous stresses in society and often in the family itself, many parents worry about their ability to help their children develop the values and skills that will enable them to succeed as adults.

Sometime in early to middle adolescence, many young people begin to use and abuse alcohol, tobacco, and illicit drugs.

In particular, there is recognition that in early to middle adolescence (and sometimes earlier), many young people begin to use and abuse alcohol, tobacco, and illicit drugs. For many of these young people, substance abuse is only the most recent manifestation of antisocial or other problem behaviors that developed during childhood years, a time when they were most closely supervised by their families. For a variety of reasons, their families were unable to prevent or arrest these early problems and the later onset of substance abuse in their children. When these problems escalate during early adulthood, the result is often a lack of motivation or an antipathy toward the pursuit of socially approved pathways to income and education. These young adults may then, in turn, be unable to effectively nurture their own children. Some may use violence as a primary problem-solving tool.

There is increasing recognition that such problems do not merely characterize a few very troubled youth, but are found in significant numbers of American families. And although it is clear that the problems of substance abuse are not necessarily associated with poverty, families with limited social and economic resources are particularly vulnerable.

However, family problems do not exist in isolation. They also exist and must be addressed within communities. The policies, resources, attitudes, and support networks found within a community can provide opportunities for families to learn healthy ways to meet their needs and address their problems.

The purpose of this guideline is to present the audience with ways to work with families to address the risks that may lead children to substance abuse. The prevention approaches described here are based on both research and practice evidence on family-centered strategies to prevent substance abuse among youth.

## Rationale for the Family as a Focal Point for Substance Abuse Prevention

Family and community life are the contexts within which young children cultivate desired prosocial behaviors that will lay the foundation for adolescent development. Children develop over time, learning, relearning, and adding new skills in each developmental period in their lives. As they grow, living within the context of the nurturing available from their parents and life experiences that may be enhancing or damaging, they undergo successes and failures, gains and losses, growth and setbacks. As they grow older, the influence of peers plays an increasing role in their lives. Some children emerge into adolescence with advanced prosocial skills, whereas others may have many problems (biological or interpersonal) that inhibit development of these skills. A child's limitations in coping with some of the problems that are known risk factors for substance abuse can be the precursor from which adolescent substance abuse emerges.

Although substantial accuracy can be claimed for the foregoing portrait of children, families, and communities, practitioners of substance abuse prevention often do not design their interventions accordingly. Frequently, they do not begin addressing the problem until adolescence, although data indicate that it begins in childhood. Further, they overwhelmingly promote school-based prevention strategies that target the child or adolescent and his or her peers, but neglect the family context. Finally, although it is well documented that the capacities of families are related to the support they receive from the communities in which they live, the presence of that support, as well as gaps and needs in support systems, are rarely acknowledged or assessed in preparing for prevention interventions. This guideline presents prevention approaches that take these factors into account, demonstrating evidence of effectiveness.

### Family Life and the Development of Children

Family life provides the critical context for the nurturing and development of children into healthy, competent, and caring adults. For some, this context includes one or two parents and siblings. For others, this context includes an extended network of family members who are biologically related or who are "like family." For still others, this context includes a community of people, such as a church community, a cultural community, or a closely knit neighborhood, with whom the family closely identifies and who are committed to the joint effort of raising their children.

The members of a family, however defined, are interdependent in their functioning. Each has roles and responsibilities that are crucial to the success and support of the entire family. Whatever limits or weakens the capacity of one member to carry out his or her roles or responsibilities weakens the entire family. Likewise, the steps taken to strengthen the entire family have a positive impact on all family members.

### Community Life as the Context for Families

Children need families that have time for them; that eschew violence and discord as methods for solving problems; that have values and rules that sustain and protect their family life together; that keep them safe and protected; and that meet basic needs, such as food, housing, health care, and education. Just as children need the nurturing, stimulation, protection, and resources that caring adults can provide, families need such support from a caring community. All families need decent housing, safe neighborhoods, adequate schools, access to health care, income from employment, and respect from others for their culture. Some families meet these needs with relative ease and require only occasional support for specific problems that may arise. Others have greater difficulties and need protracted support and assistance.

A smaller percentage of families have the greatest need for resources and support but have only marginal capacities to find and use those resources. These families may need active intervention to ensure the protection of children and family members. Even for these families, however, interventions must involve them fully in the solutions, build on family strengths, and preserve family integrity.

## Definitions Used in This Guideline

A number of terms used throughout this guideline have specific meanings within the context of family-centered prevention. These terms are defined and discussed here to assist the reader in using the guideline.

### Family

This guideline addresses interventions for families with school-aged children (parents or parent figures who are raising children between 5 and 18 years of age). For the purposes of this guideline, therefore, family is defined as parents (or persons serving as parents) and children who are related either through biology or through assignment of guardianship, whether formally (by law) or informally, and who are actively involved together in family life - sharing a social network, material and emotional resources, and sources of support. Persons serving as parents can be foster, adoptive, or divorced parents, stepparents, or extended family members or friends with formal or informal guardianship of children. In a given household, the family may include one or two parents and/or guardians, children, extended family members, and other individuals regularly living there who are involved in the ongoing care of the children.

### Prevention

As most who work in the field of prevention are aware, agreement on a definition of prevention is problematic. The traditional definition, which has been used for a broad range of prevention efforts, draws upon the public health classification system of disease prevention first proposed by the Commission on Chronic Illness in 1957, cited in the Institute of Medicine (1994). According to this schema:

- Primary prevention efforts seek to decrease the number of new cases of a disorder.
- Secondary prevention efforts seek to lower the rate of established cases.
- Tertiary prevention efforts seek to decrease the amount of incapacity associated with an existing condition.

According to the above public health definitions, primary prevention efforts are suitable for the general population, secondary prevention efforts focus on high-risk populations that are beginning to exhibit a problem, and tertiary prevention efforts address the needs of persons who are already experiencing a problem. This traditional definition of prevention, however, has become increasingly difficult to apply because of the complexity of biological, psychological, and social factors associated with substance abuse and the interplay between risk factors and mitigating protective mechanisms. Targeted populations and the interventions directed toward them do not fall neatly into one slot. It has become increasingly difficult to make distinctions between prevention and treatment.

An alternative classification scheme for prevention offered by Gordon (1983, 1987; also cited in Institute of Medicine, 1994) is used in this guideline. Gordon has operationally classified prevention measures on the basis of the population groups for which they are optimally used, incorporating an assessment of the benefits and the costs of addressing various populations. In the application of this scheme to family-centered substance abuse prevention, the benefits of addressing populations at various degrees of risk for substance abuse are weighed against the cost to society of carrying out interventions with these families.

Gordon defined the three categories of universal, selective, and indicated preventive measures as follows:

- Universal Preventive Measures are directed toward a general population. In the context of family-centered substance abuse prevention, universal measures are directed to general population groups that have not been identified on the basis of risk factors related to substance abuse (i.e., have no known risks) but for whom exposure to prevention strategies could reduce the possibility of substance abuse. Universal prevention strategies are beneficial in that they address a wide-ranging audience that includes everyone who might possibly gain something. Although a universal preventive measure can be brief, resulting in a low cost per family, some costs will be incurred in providing prevention strategies to families who do not need them.
- Selective Preventive Measures are directed to members of subgroups of the population whose risk of developing problems is above average. In the context of family-centered substance abuse prevention, selective measures are directed to families with children who do not yet abuse substances but who, as a subgroup, have an above average risk for developing substance abuse problems. The benefit of selective preventive measures is derived from the opportunity to focus intensively on groups of families who may have a greater than average need for these interventions. These tailored interventions may be more expensive per family, and costs may be incurred for families who do not engage in or sustain participation in the program.
- Indicated Preventive Measures are applied to individuals who, on examination, are found to manifest a risk factor, condition, or abnormality that identifies them as being at high risk for the future development of a problem. When used in the context of family-centered substance abuse prevention, indicated measures are directed to specific families (as opposed to subgroups of families) whose children are not abusing substances but who have known, identified risk factors for doing so. The benefit of using indicated preventive measures lies in the capacity to target those families with the most serious problems and to design interventions to meet their specific needs. These interventions have a high cost per family; these families are beset by such serious difficulties that the interventions must be lengthy and comprehensive to be successful. Further, families with these difficulties are often unable to marshal the motivation and resources needed to participate or remain in the program until they can realize its full benefits.

Families receiving prevention interventions that employ universal and selective measures are usually recruited from general populations or from higher risk subgroups. For this reason, these interventions are likely to include families at higher risk than the intervention is intended to address. Thus, it is important that these interventions incorporate referral resources for families who may need more assistance than the intervention is designed to provide.

In making complex decisions about the choice of substance abuse interventions, this set of definitions is likely to be more helpful to program developers than the traditional set. Program developers can use this framework to make relative judgments by weighing numerous factors, including benefits and costs, rather than thinking only in terms of three exclusive choices. Local communities can decide which risk factors to target based on the interplay of local community and family dynamics, resources, and problems. Table I-1 summarizes aspects of this broader definition of prevention that can be considered when making these decisions.

Table I-1: Characteristics of Substance Abuse Preventive Measures

Type of Measure | Target Population* | Primary Goals | Primary Benefits | Cost Considerations
Universal | All families in a common setting that is not distinguished by degree of risk (i.e., school district, community, or religious institution). | To teach parents and children how to recognize the risk and protective mechanisms for substance abuse and how to improve family life to reduce risks and enhance protective factors. | Provides every family with the basic skills to address general concerns about substance abuse and with a knowledge base to recognize substance abuse risks and problems. Provides families general support in raising their children to avoid substance abuse problems. Benefits communities by giving all families a source of support in preventing substance abuse. | High costs are incurred by serving everyone, including families who do not need help. Cost per family can be low because the intervention is less intensive than other measures and does not address specific risks.
Selective | Families who share common general risk factors for substance abuse, such as economic deprivation, single-parent household, and location of home in high-risk community. | To teach parents and children specific skills to improve family interaction patterns and family management practices in order to reduce risks of antisocial behavior and accompanying substance abuse and to enhance prosocial behavior. To provide families with the opportunity to practice skills in a supportive environment. | Benefits families and children who may be struggling with unusual stress in coping with difficulties in their lives, thus making them more vulnerable to substance abuse. Offers support and opportunities to children and families to prevent problems from becoming more serious. Benefits communities by addressing problems before they become entrenched in individual families. | Costs are focused on families who may need extra help, and interventions are enhanced by targeting high-risk populations. Intervention may be more expensive per family because of the need to address the specific risks of participating families.
Indicated | Families with children who already exhibit diagnosed or documented antisocial behavior, conduct disorder problems, or other behavior problems that place them at risk for substance abuse. | To provide parents and families with sustained therapeutic counseling, therapeutically focused parent or family skills training, or in-home services designed to intervene in a specific family. To reduce the risks of behavior problems and accompanying substance abuse and enhance prosocial behavior. To provide extensive opportunity for families to integrate new behavior patterns and skills. | Benefits families and children who have already diagnosed problems, such as antisocial behavior, and communities that are experiencing the consequences of that behavior. | Interventions, and therefore, costs are targeted to those most in need. Cost per family is high because intervention requires sustained, intensive efforts by a family therapist.
*For all measures, the target population is composed of families whose children are not abusing alcohol, tobacco, or illicit drugs. SOURCE: Gordon, R. (1983). An operational classification of disease prevention. Public Health Reports 98(2),107--109.

### Effectiveness

In this guideline, the term effectiveness is used to describe the degree to which a prevention approach or intervention achieves specified objectives or outcomes. Program evaluators generally use two terms when assessing the general concept of effectiveness - "efficacy" and "effectiveness." Efficacy evaluation is used when an intervention is assessed under ideal program conditions - usually a well-funded project conducted by researchers. Effectiveness evaluation assesses an intervention under practice conditions - typically, the implementation of an intervention in the field (Windsor, Baranowski, Clark, & Cutter, 1994). In this guideline, evidence based on both types of effectiveness evaluation has been considered in reviewing prevention interventions.

### Substance Abuse

The term substance abuse broadly refers to the consumption of psychoactive drugs in such a way as to significantly impair an individual's physical, psychological, or emotional health; interpersonal interactions; or functioning in work, school, or social settings. With regard to minors, the term refers to their use of any psychoactive substance that only adults may purchase (i.e., alcohol and tobacco) or of illicit substances, including marijuana and hashish; cocaine and crack cocaine; heroin; phencyclidine (PCP); steroids; so-called "designer" drugs or illicit synthetics; inhalants; and psychoactive prescription and nonprescription medications. According to this definition, any level of use by minors of any of these substances is considered substance abuse.

### Antisocial and Other Problem Behaviors

Most families with children experience child conduct and behavior problems. These behaviors vary greatly with regard to frequency, severity, type, impairment, and consequences. Some children occasionally break minor rules, resulting in negligible consequences, whereas others engage in persistent patterns of aggression and delinquency whose consequences are more serious. The child problem behaviors experienced by most families lie somewhere between these two extremes.

This guideline focuses on interventions designed for families with children who may have behavior-related problems or disorders or both. Thus, in this document, the term antisocial and other problem behaviors can describe either behavior-related problems or behavior-related disorders or both.

#### Behavior-Related Problems

Children with behavior problems that are isolated or intermittent can be said to have behavior-related problems. These problems, which may be characterized by episodes of impulsiveness, aggression, destruction, negativity, disobedience, and hyperactivity, are not part of a persistent behavior pattern and vary in severity and seriousness of their consequences. For instance, occasional episodes of impulsiveness or disobedience are often considered a natural part of the development process and require no professional attention. In other cases, serious but intermittent episodes of aggression or destruction may prompt parents to seek help with child management. In this guideline, families receiving interventions using selective or universal measures for preventing substance abuse are considered likely to have children with behavior-related problems.

#### Behavior-Related Disorders

Children with behavior problems that occur in persistent patterns and characteristic clusters and that cause clinically significant impairment are said to have behavior-related disorders. These disorders are defined by mental health professionals as mental disorders and often cause family distress that necessitates clinical management for the child and assistance for the parents. In this guideline, children of families receiving interventions using indicated measures for preventing substance abuse are likely to have one of a handful of mental disorders related to child conduct problems.

In particular, disorders related to behavior and conduct problems include attention deficit hyperactivity disorder (ADHD), conduct disorder, and oppositional defiant disorder. As is true for behavior-related problems, these disorders range in intensity and impairment from mild to severe. Table I-2 illustrates the characteristics of four disorders that are associated with child and adolescent conduct and behavior problems.

Table I-2: Behavior-Related Disorders

Disorder | Prominent Characteristics
Attention deficit hyperactivity disorder | Persistent pattern of inattention and/or hyperactivity and impulsivity.
Conduct disorder | Repetitive and persistent pattern of violating the basic rights of others or major age-appropriate societal norms or rules. Can include aggression to people and animals, destruction of property, deceitfulness or theft, and serious violation of rules.
Oppositional defiant disorder | Recurrent pattern of negative, defiant, disobedient, and hostile behavior toward authority figures. Includes some features of conduct disorder but does not include the persistent pattern of violating the rights of others or major societal norms or rules.
Adjustment disorder | Clinically significant emotional or behavioral symptoms in response to a psychosocial stressor. Includes distress in excess of expectations or significant impairment in social or academic functioning.
SOURCE: Adapted from American Psychiatric Association. (1994). Diagnostic and statistical manual of mental disorders (4th ed.). Washington, DC: Author.

## Content of the Guideline

Each of the five chapters of this guideline explores a different aspect of family-centered approaches for preventing substance abuse among children and adolescents.

Chapter 1, Substance Abuse Problems and the Status of the American Family, describes the status of families in American society with respect to key demographics and statistics about the problem of substance abuse in families, specifically for women and youth. Following the discussion of the patterns of substance use in the general population, in women, and in adolescents, as well as an overview of the risks associated with adolescent substance abuse, is a description of the stressors that create an environment in which both children and adults are at high risk for substance abuse. Chapter 1 provides the rationale underlying the family-centered prevention approaches discussed in the remainder of the guideline.

Chapter 2, Risk and Protective Factors and Developmental Models in the Etiology of Substance Abuse, explores the factors in children's lives that predispose them to, or protect them from, the risk of substance abuse. The complex and interrelated circumstances that make it likely that a child will abuse drugs in adolescence have been studied extensively by many researchers. Increasingly, investigators are also examining those mechanisms that interact with these risk factors to prevent or ameliorate their effects. This chapter explores the ways in which these risk and protective factors interact and the etiological models that explain how substance abuse and other antisocial behaviors develop in young people. Finally, a brief overview is given of the prevention approaches that are based on these etiological models and that are presented in greater detail in chapter 3.

Chapter 3, Analysis of Evidence and Recommendations for Practice, presents an analysis of the effectiveness of three family-centered approaches to the prevention of substance abuse in youth: parent and family training, family in-home support, and family therapy. The chapter includes an analysis of research and practice evidence for these prevention approaches as well as suggestions, recommendations, and interpretations from the Prevention Enhancement Protocols System (PEPS) Expert Panel.

Chapter 4, Program Development and Delivery of Family-Centered Prevention Approaches, discusses appropriate methods to assess, plan, deliver, and evaluate family-centered approaches to prevent substance abuse. This chapter describes specific issues that practitioners should address to maximize the effectiveness of implementation efforts. It also includes relevant research and practice findings from chapter 3 that illustrate the challenges faced by practitioners during program development and delivery.

Chapter 5, Emerging Areas of Research and Practice, explores two constructs, resilience and family support, that are widely incorporated into prevention practice but for which the level of research evidence is still relatively unknown. The stringent evidence-based process for examining the prevention approaches presented in chapter 3 resulted in the exclusion from that chapter of some issues that did not meet the criteria for sufficient research and practice evidence; however, these issues may be of great interest to practitioners. Therefore, chapter 5 presents the status of research and evaluation of these two constructs to enable practitioners to take them into account when planning interventions.

## Inclusion and Exclusion of Research and Practice

Chapters 2, 3, and 4 provide the reader with review, evaluation, and recommendations regarding three family-centered prevention approaches: parent and family training, in-home support services, and family therapy. However, the broad field of family-centered prevention is not limited to these approaches. Especially in chapter 3, decisions to include or exclude family-centered prevention approaches were based on a selection protocol with inclusion and exclusion criteria, the key inclusion criteria being that sufficient research evidence be available to assess their effectiveness. Appendix B provides a complete description of the research and practice search protocols used to develop this guideline.

### Adequacy of Evidence

The first criterion for inclusion was that a potential prevention approach have sufficient research and practice evidence - that is, enough research studies and practice cases must have existed to be reviewed and evaluated. A prevention approach must have been addressed by at least three intervention research studies. Prevention approaches having practice evidence but no research evidence were excluded. Many prevention practice cases were excluded because the programs did not sufficiently document process evaluation activities. Prevention approaches that were excluded on the basis of insufficient research and practice evidence included parent leadership, parent peer support, parent involvement in youth substance abuse prevention programs, parent-child activities, and parent education.

As stated earlier, because of an inadequacy of research evidence, two potential prevention approaches, resilience and family support, were excluded from formal review and analysis in chapter 3. However, they are described and reviewed in chapter 5 as emerging areas of research and practice.

### Relevance to Topic

Research evidence was evaluated with regard to relevance to the topic of family-centered substance abuse prevention and application of an intervention to prevent substance abuse among children and adolescents. The criteria stated that the child, rather than the family, was the target of prevention efforts; the treatment group had to comprise more than 10 subjects; the intervention study had to have relevant outcome measures; the target children had to be at least 5 years old; and the target children must not have been selected on the basis of a diagnosis of a substance abuse disorder.

Treatment interventions for substance abuse among adolescents were not reviewed in this guideline because this problem falls outside the definition of prevention used here (see the earlier section, Definitions Used in This Guideline). For the purposes of this guideline, however, programs that treat substance abuse problems of parents in a family setting are considered to be prevention strategies, because they serve to reduce the risk of substance abuse in the family's children.

In summary, this guideline does not review and analyze all family-centered approaches to preventing substance abuse among youth. Neither does this guideline provide an exhaustive review of all of the many types of practice programs currently in use. Rather, it reviews and analyzes a group of family-centered prevention approaches for which there is sufficient research and practice evidence to evaluate and from which to learn. Ideally, this information can help policymakers and decisionmakers, practitioners, and researchers make informed decisions regarding family-centered substance abuse prevention programs.

The process of developing this guideline series is based on recognition of the importance of the relationship between research and practice - and that substance abuse research and practice greatly impact one another. It also illustrates that in some areas, research is more advanced than prevention practice, but in other areas, research must catch up. Most important, developing the PEPS guidelines reemphasizes the need for an ongoing dialog between research and practice and hence, between researchers and practitioners.

## References

American Psychiatric Association. (1994).Diagnostic and statistical manual of mental disorders
Gordon, R. (1983).Public Health Reports, 98
Gordon, R. (1987).Preventing mental disorders
Institute of Medicine. (1994).Reducing risks for mental disorders: Frontiers for preventive intervention research
Windsor, R., Baranowski, T., Clark, N., & Cutter, G. (1994).Evaluation of health promotion, health education, and disease prevention programs.