# About This Guideline

The Prevention Enhancement Protocols System (PEPS) is a systematic and analytical process that synthesizes a body of knowledge on specific prevention topics. It was created by the Division of State and Community Systems Development of the Center for Substance Abuse Prevention in the Substance Abuse and Mental Health Services Administration (CSAP/SAMHSA) primarily to support and strengthen the efforts of State and territorial agencies responsible for substance abuse prevention activities. The PEPS program is CSAP's response to the field's need to know "what works," and is an acceptance of the responsibility for leading the field with current information supported by the best scientific knowledge available.

This second guideline in the PEPS series summarizes state-of-the-art approaches and interventions designed to strengthen the role of families in substance abuse prevention. This topic was chosen in response to the field's expressed need for direction and in recognition of the important role of the family as the first line of defense against the dangerous, insidious, and addictive consequences of substance abuse.

## The PEPS Development Process

The development of a PEPS guideline begins with the deliberations of a Planning Group comprising nationally known researchers and practitioners in the field of substance abuse prevention. With input from their colleagues in the field, these experts identify a topic area that meets pre-established criteria for developing a guideline. A Federal Resource Panel (FRP) with representatives from appropriate Federal agencies then convenes to discuss the proposed content of the guideline. The FRP, taking into consideration recommendations from CSAP and the PEPS Planning Group, identifies those experts in the field best suited to serve on an Expert Panel for the chosen topic.

Once formulated, the Expert Panel meets to determine the scope of the problem to be addressed in the guideline. The PEPS staff conducts exhaustive searches for relevant research and practice information, guided by the knowledge of the Expert Panel and its chair. The studies and practice cases found are extensively analyzed and their findings compiled and presented in draft form according to the similarity of the prevention approaches used.

A subpanel of selected Expert Panel members then meets to apply the PEPS Rules of Evidence (described later in this section) to formulate summary judgments on the quality of the research and practice evidence, by approach, and to develop recommendations for the prevention field. This draft is reviewed by the full panel. A revised version of the guideline, including the revisions of the Expert Panel, is distributed for extensive review by the field. The critique and analysis received are used to further refine and increase the accuracy, readability, and presentation of the guideline.

## PEPS Series Goals

The primary goal of PEPS is to develop a systematic and consistent process for improvement of substance abuse prevention practice and research. Its objectives are to

- synthesize research and practice evidence on selected topics,
- present recommendations for effective substance abuse prevention strategies in versions suitable for several target audiences,
- ensure that PEPS products receive optimal dissemination among target audiences, and
- monitor the usefulness and relevance of PEPS products.

Although lessons from available science are distilled and specific recommendations are made, this guideline is not a "how-to" handbook, nor is it a prescriptive prevention planning guide. Audiences for PEPS products include State prevention agencies, other Federal and State authorities, and community-based organizations addressing the problems of substance abuse or serving populations at high risk. Therefore, targeted users of PEPS guidelines include policy analysts and decisionmakers, who need sound data to justify funding for prevention planning; State agency and community-based administrators and managers, who will find the series useful in allocating resources and planning programs; researchers, who will receive guidance on the need for future studies; and practitioners, who will find recommendations for programming options that are most appropriate for the populations they serve.

## The Scope of This Guideline

Preventing Substance Abuse Among Children and Adolescents: Family-Centered Approaches focuses on research and practice evidence for a select number of approaches to the prevention of family-related problems. The criteria used for inclusion of studies in this guideline (described in appendix B) excluded some research and practice evidence. Although other conceptual or practice approaches do exist, sufficient documentation of their use is not yet available. This guideline describes the following three prevention approaches:

1. Parent and Family Skills Training.
2. Family In-Home Support.
3. Family Therapy.

The information included in this guideline was used to develop two additional publications: a Practitioners' Guide and a Parents' and Community Guide. The Practitioners' Guide summarizes much of the information in this guideline and highlights practical information that is most useful to those directly involved in planning and implementing prevention programs. The Parents' and Community Guide provides a brief overview of substance abuse problems and courses of action for concerned citizens, and provides tips for becoming involved in family-centered prevention.

## Levels of Evidence

At the heart of the guideline development process are several concepts concerning the weight of evidence that makes research or practice information strong enough to serve as the basis for recommendations. Because these concepts are at the foundation of understanding the rigorous process used to develop this guideline, they are explained in detail in this introductory section.

The term research evidence refers to the research-based body of knowledge that exists for a specific prevention approach. This information is gained from scientific investigations that range in design rigor from experimental to quasi-experimental to nonexperimental. The term practice evidence describes information gained from prevention practice cases, information generally presented in the form of well-designed and -executed case studies that include process evaluation information on program implementation and procedures.

In chapter 3, the description of each prevention approach includes at least one shaded box that presents information on levels of evidence. These boxes highlight the consensus of the Expert Panel on conclusions that can reasonably be drawn from an analysis of the research and/or practice evidence for each approach. These boxes also indicate the strength of the level of cumulative evidence supporting the conclusions. The criteria for assigning levels of evidence are shown in the following boxes. The first three categories for level of evidence indicate the extent of research and practice evidence for rating the varying degrees of confirmation of positive effect. The fourth category applies to research and practice evidence indicating that a prevention approach is ineffective.

Strong Level of Evidence

Application. This level of evidence means that practitioners can use a prevention approach with the most assurance that the approach can produce the particular effect specified in the evidence statement.

Medium Level of Evidence

Application. This level of evidence means that although the number or rigor of the studies reviewed is limited at this time, there is still substantial support for a prevention approach's ability to produce the particular effect specified in the evidence statement. Practitioners can proceed but should exercise discretion in application and in assessment of process and outcomes.

Suggestive but Insufficient Evidence

This category is used to describe research and/or practice evidence that (1) is based on a plausible conceptual model or on previous research and (2) is being demonstrated in rigorous evaluation studies or appropriate intervention programs currently in process. One of two conditions typically causes evidence to be described as suggestive but insufficient:

a. In the first condition, the evidence, although limited, appears to support a conclusion, but additional research is needed to fully support the conclusion. This condition often applies to areas in which there has been little study, such as those that are impractical to research or new areas of study.
b. A second condition involves equivocal results. In this condition, a specific conclusion is supported in some studies but is not supported in others.

Application. This level of evidence means that the prevention approach has shown promise for the effect specified but should be regarded as not well documented. Practitioners should be cautious about undertaking approaches with this level of evidence. However, depending on local circumstances, should the approach fit the situation and merit adoption, special attention should be given to its systematic testing and documentation.

Substantial Evidence of Ineffectiveness

This category describes research and practice evidence demonstrating that a prevention approach is not effective. The criterion for inclusion in this category is the absence of a statistically significant effect or a statistically significant negative effect in a majority of well-executed studies, including at least two quantitative studies with sample sizes sufficient to test for the significance of the effect.

Application. This level of evidence means that the approach has not demonstrated the intended results or has shown negative findings for the particular effect specified. Practitioners should avoid these approaches because they offer no promise of success at this time.

### Using Levels of Evidence in Program Planning

Because prevention activities vary in their emphasis, scope, and content, no two research studies or practice cases are the same. As they differ in the subjects of evaluation and in the methods used, it is difficult to reach a single conclusion about a particular approach. Additionally, there may be varying levels of evidence for different desired results of a prevention approach, as shown by similar findings from more than one study. Therefore, more than one evidence statement may be made to identify and rate conclusions that can be drawn from evidence available on a single approach. For instance, studies may show that a prevention approach has strong evidence for attaining a desired effect in the short term, but suggestive but insufficient evidence for sustaining that effect over time.

The prevention approaches presented in this guide should be considered in light of local circumstances; it may not be feasible to implement only those approaches with a strong level of evidence. Local needs, interests, resources, and abilities - as well as the level of evidence - must all be considered when planners and practitioners make program development choices.

## Recommendations for Practice

Following analysis of evidence for each approach, a special section outlines recommendations for practice. This section presents the PEPS Expert Panel members' recommendations, suggestions, observations, and interpretations regarding the prevention approach evaluated in the preceding text. General recommendations and suggestions that are applicable to more than one prevention approach appear later in the chapter.

### Types of Recommendations

The recommendations for practice vary considerably in nature and intent. Some are practical suggestions for optimal implementation of a particular intervention while others suggest techniques and cautions to avoid problems. A few are practical observations about what to expect during certain prevention activities. Others interpret research findings or illustrate the practical context of prevention efforts. Some recommendations reflect expert opinions of the panel members, such as assumptions and hypotheses that drive certain prevention activities. Many represent "best practices" among prevention experts. Some recommendations relate to implementation of specific prevention interventions. (A comprehensive discussion of implementation is presented in chapter 4.)

### Basis of Recommendations

These recommendations are based on the research and practice evidence reviewed in the Analysis of Evidence section, additional evidence not described in the section, and the professional experience and opinions of Expert Panel members. Many recommendations are derived from the experiences of Expert Panel members involved with research or practice activities that are not explicitly described in this chapter.

These recommendations represent the transfer of practical information from prevention research and practice experts to prevention decisionmakers, such as State and local prevention authorities, other prevention practitioners and researchers, and members of community prevention organizations.

## A Request to Readers

Based on comments received from users of the first guideline, Reducing Tobacco Use Among Youth: Community-Based Approaches, several significant changes have been made in the structure and presentation of this publication. CSAP actively seeks a continuing dialog with its constituents on the extent to which they find this series useful and the ways in which future guidelines may be improved. Therefore, comments are actively solicited for inclusion in revisions of this guideline or in production of future guidelines. They should be referred to: PEPS Program Director, Division of State and Community Systems Development, Center for Substance Abuse Prevention, SAMHSA, 5600 Fishers Lane, Rockwall II, Rockville, MD 20857.