# Planning Group Overseeing Development of PEPS Documents

- Richard R. Clayton, Ph.D., Chair
- Thomas E. Backer, Ph.D.
- Leonard G. Epstein, M.S.W.
- Bettye Ward Fletcher, Ph.D.
- Jean L. Forster, MD, M.P.H.
- William M. Harvey, Ph.D.
- Ralph W. Hingson, Sc.D.
- Jan Howard, Ph.D.
- Ford H. Kuramoto, D.S.W.
- Jeffrey N. Kushner, M.A.
- Andrea L. Mitchell, M.L.S.
- Abdin Noboa, Ph.D.
- Pamela Petersen-Baston, M.P.A., C.A.P.
- Eva L. Petoskey, M.A.
- Robert I. Reynolds, M.A.
- Robert G. Robinson, Ph.D.
- Robin G.W. Room, Ph.D.
- Zili Sloboda, Sc.D.
- José Szapocznik, Ph.D.
- Ralph E. Tarter, Ph.D., M.P.A.
- Mel Tremper, Ph.D.
- Friedner D. Wittman, Ph.D., M.Arch.