# Emerging Areas of Research and Practice

Practitioners reading this guideline may wonder why certain prevention approaches and strategies that are widely used (and perhaps supported by a strong funding base) are not discussed in chapter 3. Several types of family-centered prevention interventions were excluded from extensive analysis in this guideline because they did not meet specific inclusion criteria of the Prevention Enhancement Protocols System (PEPS), despite their use in prevention practice. Some of these criteria are an ample body of research or practice evidence for review and analysis, soundness of the studies' research design, appropriate age of the intervention subjects, and documentation of process evaluation for prevention practice cases.

Two constructs not previously examined in this guideline are resilience and family support. They are described as constructs because they are in the early stages of research, even though each has a theoretically based field of practice. This chapter identifies their theoretical bases and describes their status in prevention research and practice. This information is intended to assist practitioners, policymakers, and other decisionmakers in their understanding of these areas. It is hoped that practitioners and researchers will build on this information when implementing prevention interventions and contribute to the knowledge base in these emerging areas.

While still in the early stages of research, resilience and family support are prominent constructs that have emerged in prevention practice.

## Emergence of the Constructs of Resilience and Family Support

Over the past two decades, prevention research has increasingly focused on the importance of the family's role in nurturing prosocial behavior in children and on understanding how prosocial and antisocial behaviors develop. Prevention practitioners most commonly use interventions designed to reduce risk factors and enhance protective factors to help families encourage prosocial behaviors in children. Although there has been considerable research on the significance, hierarchy, and interaction of risk factors, far less research has been conducted on protective factors. Questions that have been left unanswered include the following:

- Why do many children and families achieve positive outcomes despite numerous and severe obstacles?
- Why do these same obstacles prevent other families from reaching positive outcomes?
- What are the qualities and characteristics of family interventions that best help families develop the capacity to act on their own behalf and deal effectively with their environments?
- What are the qualifications, experiences, and skills of practitioners that help families develop these capacities?
- What is the role of social support systems, both formal and informal, in enhancing family and child development?

Studies of resilience and family support have attempted to address these questions. These two constructs have arisen from a number of observations of practitioners and researchers involved in family-centered prevention. For example, there is a need to identify enduring solutions that more effectively use available assets, capacities, and resources of both families and communities. In particular, families have a capacity for growth and development that traditional service systems do not effectively mobilize. Most families can benefit from assistance that anticipates and provides the support children need to meet the challenges of their developmental tasks (rather than assistance that waits until problems emerge). It is also important to understand the interactional influences among the child, the family, and the community environment.

Challenges that remain with regard to these constructs are the delineation of their elements and dimensions and the development of methods to appropriately evaluate interventions based on these working concepts.

Developing the construct of resilience is complicated by a lack of consensus regarding definition of the term.

### The Construct of Resilience

Exploring the construct of resilience has been stimulated by empirical observations from several sources, which follow:

- Findings from etiological studies about stress and coping with severe deprivation, especially by survivors of wars and catastrophes (Epstein, 1979; Goldfarb, 1943; Harbison, 1983; Jahoda & Harrison, 1975; Langmeier & Matejcek, 1975; Leavitt & Fox, 1993; Rutter & Quinton, 1984; Spitz, 1945, 1946; Thoits, 1983).
- Findings from early longitudinal studies on children's stressful life course events (Elder, 1974; Elder, Liker, & Jaworski, 1984; Werner, 1989; Werner & Smith, 1982, 1992).
- Related research and practice driven by limited resources to serve large numbers of troubled families and designed to help families improve and enhance their ongoing capacity to solve their own problems, rather than be dependent on others to solve them.

#### Defining Resilience

Developing the construct of resilience is complicated by a lack of consensus regarding the meaning of the term. It is generally agreed that resilience involves competence or positive, effective coping in response to risk or adversity (Luthar & Cushing, in press). Literature suggests that resilience to adolescent onset of substance abuse may be defined as either of the following capacities of children (Herrenkohl, Herrenkohl, & Egolf, 1994; Luthar, 1991; Luthar & Cushing, in press; Turner, Norman, & Zunz, 1993):

1. The capacity to recover from traumatic life events (e.g., the death of a parent, divorce, sexual abuse, homelessness, or a catastrophic event) and other types of adversity to achieve eventual restoration or improvement of competent functioning.
2. The ability to withstand chronic stress (e.g., extreme poverty, alcoholic parents, chronic illness, or ongoing domestic or neighborhood violence) and to sustain competent functioning despite ongoing adverse life conditions.

Although there is widespread divergence of opinion on how resilience should be measured, resiliency researchers sometimes seek to measure the competency of children by examining their degree of success in meeting important societal expectations and requirements for various types of social conduct. These include school achievement, obeying the law, and successful interactions with peers who have a positive influence (Garmezy, 1993).

#### Elements of Resilience

Those attempting to describe and develop the construct of resilience have found that the ability to successfully cope with stress and adversity arises from the interaction of several elements in a child's life. These include the following:

- The child's biological makeup and internal characteristics, especially intelligence.
- The child's temperament and internal locus of control or mastery.
- The family and community environments in which the child is raised, especially the extent to which significant nurturing and supportive qualities are present.
- The number, intensity, and duration of stressful or adverse circumstances faced by the child, especially at an early age.

There is clearly suggestive evidence that each of these elements plays a role in a child's development of resilience. Further, some elements (e.g., the child's personality development) are amenable to intervention strategies, whereas others (e.g., the child's biological traits) are not. Because research on resilience is still in an early, descriptive stage, it is unknown how these elements act and interact with each other, either in children or in families (Garmezy, 1993), and many questions remain unanswered. For example, to what extent does resilience rely and build on biological traits, as opposed to learned patterns of behavior? Can everyone learn to be resilient, or must certain conditions be present? Can families and communities learn to be resilient, or only individuals?

#### Studies Addressing Resilience

The 1989 research study by E. E. Werner, whose subjects were children born on a Hawaiian island, is the best known and most frequently cited etiological study on resilience. Among the many outcomes of this remarkable study are the following:

- One-third of the children who experienced severe and extensive adverse circumstances (poor prenatal development, poverty, negative family functioning, and family disruption) developed into competent, normally functioning adults.
- The three elements in the lives of children that made the greatest difference in overcoming adversity were adequate family functioning, sources of external support, and resilient temperament (which included intelligence and a pleasant personality).
- The impact of various risk and protective factors varied depending on when they occurred in the child's development. For example, successful functioning at one point in development did not guarantee it at a later point.
- Some of the children experiencing adverse consequences grew up to be competent adults, but not necessarily psychologically well-adjusted or happy adults.

Other researchers, who examined maltreated children (Herrenkohl et al., 1994), high-risk adolescents (Luthar, 1991), and children in poverty (Garmezy, 1993), confirmed or expanded on these findings. Related research has revealed the following:

- Children do not necessarily exhibit competence in all domains at the same time. For example, they may be academically competent but unable to have close friends (Luthar, 1993).
- Children may exhibit or practice competence at great personal cost. For example, intelligent children may be more susceptible to stress than their peers because they are more sensitive to their environments (Farber & Egeland, 1987; Garmezy, 1993; Werner, 1989).
- Competence may diminish over time if an individual is subjected to enough stressors or adversity (Garmezy, 1993).

#### The Practice of Resilience-Based Interventions

The published research and evaluation studies on the construct of resilience define important etiological factors and document their interactions in the lives of children. However, virtually no intervention studies have been conducted that test the outcomes of resilience variables. Further, the arena of study has focused primarily on children, not on families.

Although none of the interventions discussed in chapter 3 were designed to evaluate resilience directly, several are closely allied to important elements of resilience (Aktan, Kumpfer, & Turner, 1996; Kumpfer & DeMarsh, 1987; Kumpfer, Turner, & Palmer, 1991). These interventions include multicomponent strategies designed to enhance protective factors, such as effective communication and family management practices at home and school, that can buffer the effects of ongoing stresses and adversity in a child's development (Catalano, Haggerty, Gainey, Hoppe, & Social Development Research Group, 1995; Hawkins, Von Cleve, & Catalano, 1991; Hawkins et al., 1992). These strategies also include therapeutic interventions designed to restore effective family functioning by building on family and cultural strengths (Szapocznik et al., 1986, 1989).

As the results of etiological research on resiliency have filtered into the practice literature, many practitioners have provided training on resiliency and its relationship to enhancing protective factors for children and families. The concept has been widely shared as a framework for highlighting the experiences of children, as many practitioners believe this construct can make a significant difference in outcomes.

#### The Status of Resilience Research and Evaluation

Most resiliency researchers agree that the construct involves interaction among the child's biological and personality characteristics, his or her environmental influences and experiences, and the ability of the child to mature psychologically (Herrenkohl et al., 1994). However, little is known about how these factors interact. Most of what is known is based on etiological studies of the associations between childhood behavioral issues and later adolescent substance abuse. Some researchers debate whether resilience is actually a protective factor and should be researched as such or if it is a separate construct and area of research that extends beyond protective factors.

Although there is reason to believe that some aspects of resilience as a construct can be confirmed through research, there are enormous barriers to research and documentation efforts. Differing perceptions of what constitutes resilience and competence, the need to sort out the complex interplay of risk and protective mechanisms, and the interactions among various domains and developmental stages must be further explored to clearly define an effective research intervention study.

### The Construct of Family Support

The self-help and community-based movements of the 1960s and the changing demographics of the 1970s influenced many practitioners in the beliefs that traditional helping strategies were not sufficient and that limited resources must be stretched further to address ever-intensifying family issues. It also became clear that, for the benefit of both families and communities, solutions to family needs must support the development of family capacities to act on their own behalf and gain control over their environment (Weissbourd & Kagan, 1989). This concept is often referred to as empowerment.

Toward this end, service providers experimented with ways to engage people more fully in activities deemed beneficial. They also investigated ways to elicit concerns and interests so that a menu of services could be tailored to the individual (National Resource Center for Family Support Programs, 1993). However, these efforts were top-down and service directed and did not achieve the results hoped for by practitioners.

The construct of family support emerged from these concerns and experiences of practitioners, as well as from the growing research literature on risk and protective factors. Family support assumes that all families have inherent competencies and capacities that can promote children's healthy development. Further, family support assumes that family-helping programs and resources must go beyond preventing problems to supporting optimum development of these capacities. Expressed in a diverse group of programs, this construct is based on a set of consensually developed principles and premises that center on the inherent skills of families to improve their own outcomes.

The driving force behind the construct of family support is the conviction that family-helping programs and resources have the responsibility to go beyond preventing problems to supporting optimum development of the capacities inherent in all families.

Family support is proactive and views parenting as a developmentally learned task in all families. The construct affirms that strategies for delivering family services should be rooted in a community support system. The strengths and assets of both families and communities are stressed as the starting point for developing family support (Dunst, Trivette, & Deal, 1988; Weissbourd & Kagan, 1989).

Through the Best Practices Project, the Family Resource Coalition (1996) brought together leading family support researchers, theoreticians, and practitioners in a series of meetings and focus groups. This led to agreement on the premises of family support, the principles of family support practice, the definition of best practices, and a conceptual framework for training in family support. The consensus report from this effort defined a set of seven "Premises of Family Support" and nine "Principles of Family Support," which together describe the family support philosophy, its underlying values, and the means by which these values are carried out in practice. These premises and principles are described in the following sections.

#### Premises Underlying the Family Support Construct

Despite the diversity of family support programs, virtually all share the same philosophical premises and underlying values, which form the point of view from which family support programs have been initiated and developed, and from which practice has emerged (Family Resource Coalition, 1996). These premises are the following:

1. Primary responsibility for the development and well-being of children lies within the family, and all segments of society must support families as they rear their children. The systems and institutions upon which families rely must effectively respond to the needs of families to establish and maintain environments that promote growth and development. This goal requires a society that is committed to prioritizing the well-being of children and families and to supporting that commitment by allocating necessary resources.
2. The cornerstone of a healthy society is the well-being of families, who should have universal access to support programs and services. A national commitment to promoting the healthy development of families acknowledges that every family, regardless of race, ethnic background, or economic status, needs and deserves a support system. Since no family can be self-sufficient, the concept of reaching families before problems arise is not possible unless all families are reached. A public mandate is therefore necessary to make family support accessible and available to all on a voluntary basis.
3. Children and families exist as part of an ecological system. An ecological approach assumes that child and family development is embedded within broader aspects of the environment, including a community with cultural, ethnic, and socioeconomic characteristics that are affected by the values and policies of the larger society. This perspective assumes that children and families are influenced by interactions with people, programs, and agencies as well as by values and policies that may help or hinder families' ability to promote their members' growth and development. The ecological context in which families operate is therefore a critical consideration in programs' efforts to help families.
4. Child-rearing patterns are influenced by parents' understanding of child development and of their children's unique characteristics, by their personal sense of competence, and by cultural and community traditions and mores. There are multiple determinants of parents' child-rearing beliefs and practices, and each influence is connected to other influences. Because the early years set a foundation for the child's development, patterns of parent-child interactions are significant from the start. The unique history of the parent-child relationship is an important consideration in a program's efforts.
5. Building on strengths, rather than treating deficits, assists parents in dealing with difficult life circumstances and in achieving their goals, and therefore enhances parents' capacity to promote their children's healthy development. Family support programs encourage development of competencies and capacities that enable families to have control over important aspects of their lives and to relate to their children more effectively.
6. The developmental processes of parenthood and family life create needs that are unique at each stage in the lifespan of the offspring. Parents grow and change in response to varying circumstances and to the challenges of nurturing a child's development. The tasks of parenthood and family life are ongoing and complex, requiring physical, emotional, and intellectual resources. Many tasks of parenting are unique to the child's developmental stage; others are unique to the parent's point in his or her life cycle. Additionally, parents have been influenced by their own childhood experiences and their own psychological characteristics, and are affected by their past and present family interactions.
7. Families are empowered when they have access to information and other resources and take action to improve the well-being of children, families, and communities. Access to resources in the community - including up-to-date information and high-quality services that address health, educational, and other basic needs - enables families to develop and foster optimal environments for all members. Meaningful experiences participating in programs and influencing policies strengthen existing capabilities and promote development of new competencies in families, including the ability to advocate on their own behalf.

#### The Principles of Family Support Practice

The accepted guidelines for this construct are built around principles that state how family support premises are carried out in programs. While specific practice strategies may be different in different program situations, they should be consistent with the principles that guide family support work. The following principles describe good family support practice (Family Resource Coalition, 1996):

1. Staff and families work together in relationships based on equality and respect.
2. Staff enhance families' capacity to support growth and development of all family members - adults, youth, and children.
3. Families are resources to their own members, to other families, to programs, and to communities.
4. Programs affirm and strengthen families' cultural, racial, and linguistic identities and enhance families' ability to function in a multicultural society.
5. Programs are embedded in their communities and contribute to the community-building process.
6. Programs advocate with families for services and systems that are fair, responsive, and accountable to the families served.
7. Practitioners work with families to mobilize formal and informal resources to support family development.
8. Programs are flexible and continually responsive to emerging family and community issues.
9. Principles of family support are modeled in all program activities, including planning, governance, and administration.

Family support theorists and practitioners put forward the following ways in which family support differs from other prevention approaches:

Opportunity Factors Versus Risk Factors. Within the construct of family support, risk factors are defined as influences that impede the development of family competence, whereas opportunity factors are those influences that facilitate and promote competence (Garbarino & Abramowitz, 1992). Rather than focusing merely on eliminating risks, interventions should promote opportunities for developing family competence. Although the concept of promoting opportunities appears to be similar to that of enhancing protective factors, family support researchers believe that this concept extends further, beyond the focus on deficits to which protective factors are tied (Dunst, Trivette, & Thompson, 1990).

Resource-Based Intervention Practices Versus Delivery to Those at Highest Risk (Greatest Need). Resource-based interventions focus on identifying and mobilizing a range and network of community social support systems that are available to everyone. This contrasts with the usual focus on the delivery of specific services that become available after diagnosis and the prioritization of scarce resources to serve those in greatest need. Three studies that examined implementing resource-based practices with families found that families progressed more effectively toward positive outcomes and viewed themselves as more satisfied with their personal control of outcomes when they acquired skills for identifying and mobilizing community resources (Trivette, Dunst, & Deal, 1996).

Family Empowerment Versus Professionally Diagnosed Services. The concept of empowerment encompasses the following three assertions: (1) People are, or have the capacity to be, competent; (2) an inability to demonstrate competence, rather than indicating inadequacies of the individual, indicates that society has failed to create opportunities for people to become competent; and 3) people seeking help must reach a point where they believe they have enough control over their lives to manage them (i.e., they attribute what happens in influencing important life events to their capabilities) (Dunst et al., 1988; Dunst & Trivette, 1994).

To empower families, practitioners need to change how they view their responsibilities and relationships with families, so that families have central roles in the development and selection of all areas of policy, practice, and services that affect them (Dunst & Trivette, 1994.)

#### Status of Family Support Practice

Over the past 10 years, the family support construct has been widely enacted in practice, providing services to families in a broad array of settings. Targeted interventions have been provided to families who are involved with the child welfare system; those who have children with disabilities; those in need of programs for child development and care; those with newborns; and those with special needs in the areas of literacy, employment, or vocational training. Numerous settings have been used to provide general support to families in the areas of recreation, parenting education, information and referral, self-help groups, home visiting programs, and parent-child interactions (Deutelbaum, 1992; National Resource Center for Family Support Programs, 1993; National Resource Center for Family Support Services, 1982; Simmens & Harrison, 1991; Weissbourd & Kagan, 1989).

Further impetus to family support practice occurred in 1993 with the passage of the Omnibus Budget Reconciliation Act of 1993. Title IV-B, Subpart 2 of the Social Security Act (Public Law 103-66) provided funds for States to develop family support programs to serve children and families who would benefit from access to family development resources but who may not qualify for support or need the resources of the formal child welfare system. This has resulted in development of pilot family support programs, passing of State laws, and provision of State and local funds to replicate family support efforts that have demonstrated successful practice.

#### Status of Research and Evaluation on Family Support

Researchers and practitioners who evaluate family support interventions believe that the traditional approach that relies only on experimental or quasi-experimental design is insufficient. They contend that the processes used to design and implement research are as important as the process and outcome findings of the research. To evaluate family support interventions, they maintain that research should embody the family support premises and principles by involving the participants in the research design and implementation processes, and by incorporating research methodologies that ensure the evaluation goals and results are "owned" by the community of users as well as researchers.

It is the deliberate exploration of these research methodologies and processes that has created a new, if still rudimentary, body of research literature for family support (Harvard Family Research Project, 1996; Whitmore, 1991). The Federal Government and a number of leading foundations are currently conducting evaluative research on family support programs that incorporate the range of methodologies described above.

Etiological researchers have focused on efforts to describe the construct, to define the elements that distinguish it from other theories or models, and to sort out significant variables. Recent and ongoing research efforts include identifying the importance of using informal resources to help families, determining how a family's style of functioning affects its capacity to cope and promote positive growth, and describing the effects of different modes of helping on an individual's ability to become more independent (Deal, Dunst, & Trivette 1989). Some researchers have suggested models of intervention (Dunst, 1995) and checklists for use by practitioners to assess the extent to which their programs implement family support principles (Dunst, 1990).

An additional, overarching problem for research on developing family support interventions has been the lack of data sources and information about family and community strengths and assets. Virtually all of the data about families describe either neutral or deficit information, problems, and needs, such as that presented in chapter 1 of this guideline. Many of the large foundation- and publicly funded research evaluations of family support projects have required community mapping (as described in chapter 4) to lay the groundwork for summarizing national and State data about community strengths.

However, data on family strengths are still inadequate and data on community strengths have not yet been summarized and analyzed to determine regional and national trends and statistics. Without national and local descriptive data about the positive characteristics of families and the areas in which they succeed, it will be difficult to identify the strengths and assets that are most useful to families.

## Conclusion

Many practitioners have developed and currently use interventions based on evolving etiological and intervention theories, especially if they make intuitive sense and address emerging problems. The constructs of resilience and family support are examples of such theories. They focus on helping families develop capacities for self-efficacy and emanate from the recognition that all families benefit from support in their development, although some may need more support than others. Interventions based on principles of resilience and family support offer program and fiscal alternatives to treatment- and deficit-focused strategies. The challenge for researchers is to keep pace with practice by further defining constructs, developing accurate measures, incorporating participatory evaluation processes, and assembling findings into an integrated body of evidence. Such efforts can help to identify and increase the mechanisms of effectiveness in these emerging areas of prevention.

## References

Aktan, G. B., Kumpfer, K. L., & Turner, C. W. (1996).Substance Use and Misuse, 31
Catalano, R. F., Haggerty, K. P., Gainey, R. R., Hoppe, M. J., & Social Development Research Group. (1995).Reducing parental risk factors for children's substance abuse: Preliminary outcomes with opiate-addicted parents.
Deal, A. G., Dunst, C. J., & Trivette, C. M. (1989).Infants and Young Children, 1
Deutelbaum, W. (1992, spring).The Prevention Report
Dunst, C. J. (1990).Family systems intervention monograph series
Dunst, C. J. (1995, June).Risk and opportunity factors influencing child and family behavior and development.
Dunst, C. J., & Trivette, C. M. (1994).Supporting and strengthening families. Volume 1: Methods, strategies and practices.
Dunst, C. J., Trivette, C. M., & Deal, A. G. (1988).Enabling and empowering families.
Dunst, C. J., Trivette, C. M., & Thompson, R. B. (1990).Prevention in Human Services, 9
Elder, G. H., Jr. (1974).Children of the Great Depression
Elder, G. H., Jr., Liker, J. K., & Jaworski, B. J. (1984).Life span developmental psychology: Historical and cohort effects
Epstein, H. (1979).Children of the Holocaust.
Family Resource Coalition. (1996).Guidelines for family support practice.
Farber, E., & Egeland, B. (1987).The vulnerable child.
Garbarino, J., & Abramowitz, R. (1992).Children and families in the social environment
Garmezy, N. (1993).Psychiatry, 56
Goldfarb, W. (1943).Journal of Experimental Education, 12
Harbison, J. (Ed.). (1983).Children of the troubles.
Harvard Family Research Project. (1996).The Evaluation Exchange,2
Hawkins, J. D., Von Cleve, E., & Catalano, R. F. (1991).Journal of the American Academy of Child Adolescent Psychiatry, 30
Hawkins, J. D., Catalano, R. F., Morrison, D. M., O'Donnell, J., Abbott, R. D., & Day, L. E. (1992).Preventing antisocial behavior: Interventions from birth through adolescence
Herrenkohl, E. C., Herrenkohl, R. C., & Egolf, B. (1994).American Journal of Orthopsychiatry, 64
Jahoda, G., & Harrison, S. (1975).Irish Journal of Psychology, 3
Kumpfer, K. L., & DeMarsh, J. P. (1987).Prevention services for children of substance-abusing parents.
Kumpfer, K. L., Turner, C. W., & Palmer, S. (1991).YCOSA Black Parenting project: Third and fourth year evaluation report.
Langmeier, J., & Matejcek, Z. (1975).Psychological deprivation in childhood.
Leavitt, L. A., & Fox, N. A. (Eds.). (1993).Psychological effects of war and violence on children
Luthar, S. S. (1991).Child Development, 62
Luthar, S. (1993).Journal of Child Psychology and Psychiatry, 34
Luthar, S. S., & Cushing G. (in press).Resiliency and development: Positive life adaptations.
National Resource Center for Family Support Programs. (1993, January).Family support programs and the prevention of alcohol and other drug abuse (AOD)
National Resource Center for Family Support Services. (1982, spring).The Prevention Report
Rutter, M., & Quinton, D. (1984).British Journal of Developmental Psychology, 2
Simmens, F., & Harrison, J. (1991, spring).The Prevention Report.
Spitz, R. A. (1945).The Psychoanalytic Study of the Child, 1
Spitz, R. A. (1946).The Psychoanalytic Study of the Child, 2
Szapocznik, J., Rio, A., Perez-Vidal, A., Kurtines, W., Hervis, O., & Santisteban, D. (1986).Hispanic Journal of Behavioral Sciences, 8
Szapocznik, J., Santisteban, D., Rio, A., Perez-Vidal, A., Santisteban, D., & Kurtines, W. M. (1989).Hispanic Journal of Behavioral Sciences, 11
Thoits, P. (1983).Psychosocial stress: Trends in theory and research.
Trivette, C. M., Dunst, C. J., & Deal, A. G. (1996).The contexts of early intervention: Systems and settings.
Turner, S., Norman, E., & Zunz, S. (1993).From risk to resiliency, a paradigm shift: A literature review and annotated bibliography.
Weissbourd, B., & Kagan, S. L. (1989).American Journal of Orthopsychiatry, 59
Werner, E. E. (1989).American Journal of Orthopsychiatry, 59
Werner, E. E., & Smith, R. S. (1982).Vulnerable but invincible: A study of resilient children.
Werner, E. E., & Smith, R. S. (1992).Overcoming the odds: High risk children from birth to adulthood
Whitmore, E. (1991).Empowerment and Family Support, 2