# Program Development and Delivery of Family-Centered Prevention Approaches

This chapter focuses on the basic steps of an implementation effort - assessment, planning, delivery, and evaluation - as applied to family-centered interventions. Relevant research and practice findings are highlighted to illustrate challenges faced by practitioners during program implementation. Table 4-1, in the following section, lists the most significant tasks necessary during each stage of implementation, as discussed throughout this chapter. The information presented here is useful for practitioners irrespective of the stage of the family intervention in which they are working. In addition to providing general guidance, the chapter sheds light on pertinent issues that arise throughout the various phases of the interventions.

Table 4-1: Specific Tasks and Activities During Program Development

Step in Program Development | Tasks | Activities
Step 1: Assessment | Develop a family and community profile of risk and protective factors. | Gather information on demographics and other social indicators.
| | Gather descriptive information (surveys, interviews, meetings).
| | Include formal and informal sources.
| Define the problem. | Compare assessment information with risk and protective factors.
| Choose target family population and prevention approach(es). | Determine where problem has the greatest impact on families.
| Choose target family population and prevention approach(es). | Assess interests, needs, concerns, and issues of families; assess their acceptance of potential approach(es).
| Assess characteristics of target families that will affect their participation. | Assess extent of support and resources from community partners.
| Assess characteristics of target families that will affect their participation. | Understand and respond to family cultures and values.
| | Understand and respond to parental attitudes and beliefs.
| Establish a process for involving families and community partners. | (See above Activities.)
Step 2: Planning | Plan partnerships with parents and community collaborators. | Identify barriers to recruitment of families.
| Plan partnerships with parents and community collaborators. | Identify barriers to participation:
| | 1. Lack of awareness of benefits.
| | 2. Cultural barriers.
| | 3. Support for basic needs.
| | 4. Negative views of approaches.
| | 5. Work-site barriers.
| | 6. Characteristics and settings.
| Address the needs of the targeted children. | Fit intervention to age, gender, and developmental stage of children from participating target families.
Step 3: Delivery | Hire and support staff. | Develop staff hiring criteria (e.g., expertise, training, interpersonal skills).
| | Develop hiring criteria specifically for facilitators and therapists.
| | Train facilitators.
| | Provide staff support (e.g., team building, facilitator meetings).
| Deliver the intervention in a partner relationship with parents. | Involve parents in delivery of the intervention.
| Deliver the intervention in a partner relationship with parents. | Encourage dialog between parents and facilitators.
| | Use parent &quot;graduates&quot; of the program in leadership roles.
| Develop strategies to monitor and retain participants. | Establish and publicize incentives for participation.
| | Monitor participant response and reasons for not participating.
| | Maintain referral network for basic support.
Step 4: Evaluation | Consult with evaluation experts. | Consider options and choose the most appropriate evaluation.
| Involve participants, staff, and other community stakeholders in the evaluation process. | Offer opportunities to participate in the evaluation design.
| Consider a variety of methods and measures to evaluate outcomes. | Choose evaluation methods and measures that accommodate the Activities of the intervention and the budget.
| | Develop unambiguous definitions of what is to be measured and explain to staff.
| Identify data sources and develop procedures for collecting data. | Identify such sources as assessments, client attendance, and feedback.
| Identify data sources and develop procedures for collecting data. | Ensure similar recording of data among different facilitators/therapists.
| | Determine scope and design needed to achieve evaluation objectives
| | and outcomes.
| | Document significant improvements in outcomes.
| Consider cost factors. | Outline cost of Activities to determine barriers to recruitment and participation.
| | Determine length of evaluation.

## Key Considerations for Program Development

During the planning stages of family-centered prevention programs, practitioners can be aided by considering the following observations, which underlie much of the information presented in this guideline.

Children vary in their levels of risk for substance use. Many conditions interact over time that help to establish risk and protective factors (described in chapter 2) that make children more likely or less likely to experiment with substance abuse. Therefore, prevention approaches should be selected according to the level of risk within the families being targeted. By categorizing preventive measures as universal, selective, and indicated measures (levels which are defined in chapter 1 and used to group interventions in chapter 3), specific approaches can be targeted to families at various levels of risk, as follows:

- Families that are not yet known to exhibit any risk factors would receive universal preventive measures.
- Families that belong to subgroups at above average risk levels would receive selective preventive measures.
- Families with children specifically known to have above average levels of risk would be targeted for indicated preventive measures.

The extent to which prevention efforts are focused on families at these risk levels is a critical planning issue for family-centered prevention interventions.

A review of the etiological and research literature addressing family-centered prevention approaches indicates some consensus about certain key findings for developing interventions. Although the following findings require further research, they can be used as a starting point for project development (Hawkins, Arthur, & Catalano, 1994; Kosterman, Hawkins, Spoth, Haggerty, & Zhu, 1997; Kumpfer & Turner, 1990--91; Loeber, 1988; McMahon, Forehand, & Griest, 1981; Spoth, Redmond, Haggerty, & Ward, 1995; Spoth, Redmond, Hockaday, & Yoo, 1997; Spoth, Redmond, Khan, & Shin, in press-a, in press-b; Yoshikawa, 1994):

1. Focus on families with young school-aged children. When possible, prevention efforts for families work best with young children, before negative behaviors and family problems become entrenched.
2. Reduce exposure to risks. Interventions can assist families in preventing the onset or reducing the impact of antisocial behavior and substance abuse by preventing or reducing exposure to risks for these problems.
3. Enhance protective factors. Interventions can also help families to promote prosocial behavior in their children by enhancing protective mechanisms that prevent, modify, or ameliorate an individual's exposure to risks.
4. Choose strategies that are developmentally and gender appropriate. To achieve maximum benefits, prevention interventions should be carefully chosen according to the developmental stages and gender of the children to whom they are directed. Important outcomes can be reinforced by appropriately revisiting interventions through several developmental stages.
5. Develop interventions in multiple contexts and settings. Because families function in and are influenced by multiple settings and environments, the needs of children and families should be addressed in as many contexts as possible, including schools, cultures, religious institutions, neighborhoods, and communities.
6. Address multiple risk and protective factors simultaneously. The most effective interventions are those that address not only multiple settings, but also multiple risk factors and protective mechanisms (e.g., reducing domestic conflict and children's antisocial behavior and improving parenting skills and school performance).
7. Build on families' strengths and encourage their leadership in the process of growth. Practitioners need to teach their skills to families so they can use this expertise to reach their goals. A family's capacity to identify and solve problems should also be supported by building on its strengths and preserving its integrity, including language and culture.
8. Recognize that families are directly affected by the level of resources, supports, and values of the communities in which they live. Family life is affected by what happens at work sites, social service agencies, schools, religious institutions, and businesses in the community. The ability of a family to balance differing community expectations and attitudes about work, culture, language, and socioeconomic status has a profound effect on the degree and type of risk factors its members may be experiencing. Families also need ready access to varying resources and support systems.

## The Assessment Stage

The initial stages of any program development effort include a process of information gathering and analysis. In the assessment stage of family-centered prevention programs, family and community risk and protective factors that point to the need for an intervention must be identified, as well as the community resources and assets available to support this intervention. The assessment stage ultimately results in a product that defines the substance abuse problem to be addressed, the target population, and the intervention approach; and it results in a process that can be used to foster community involvement and support for development and delivery of the intervention.

The desired product outcomes of the assessment include demographic and anecdotal data that profile the community and its families, organized by evident risk and protective factors. A description of the child and adolescent substance abuse problem to be addressed is another product outcome of the assessment. A group of target families who would be most affected by the problem should be identified, as well as a prevention approach likely to meet their needs. The assessment should also result in specific information about characteristics of the target families that are likely to influence their participation in the intervention. Finally, community partners who will help develop and carry out the intervention should be identified.

The desired process outcomes of the assessment include participation of a broad variety of community organizations and groups in development of the product outcomes listed above. Target families, including children and adolescents, should help identify community and family needs and strengths and gather and assess the information obtained for the product outcomes.

### Collect Family and Community Data and Organize by Risk and Protective Factors

For most communities, the prevention of substance abuse among adolescents is a significant concern. To select the most appropriate family-centered approach for a community, it is critical to identify existing problems and needs that increase the risk of adolescent substance abuse, and to identify community assets or strengths that protect against these risks by preventing, ameliorating, or reducing them. When data are organized around risk and protective factors, program developers can highlight the community and family characteristics that are the most important predeterminants of substance abuse.

The assessment process typically is comprised of two levels of data collection. First, statistical and descriptive data on families and communities is organized in the risk and protective factors framework to define the substance abuse problem, determine which target populations would benefit most from a prevention intervention, and choose the approach that will best meet the needs of this population. Second, data are collected specific to the target families to identify characteristics that will inhibit or enhance their participation.

Table 4-2 presents some suggested data that practitioners can gather to develop a profile of their communities and families. Prevention planners should supplement the available statistical demographic information by seeking the opinions and ideas of a wide variety of people who live in the community. This can be done through telephone interviews, focus groups, written surveys, meetings, and personal interviews. Regardless of the method chosen, it is essential to include families who are likely to participate in different types of approaches, including representatives of various socioeconomic strata, cultures, languages, and neighborhoods. Further, since children and adolescents are the primary target population for each of the approaches presented in this guideline, it is especially important to include them in the data gathering and analytical processes.

Table 4-2: Data Used for Developing Community and Family Profiles

Type of Data | Suggested Examples
Statistical Information About Families | Economic status of families, including those living in poverty (whether receiving public assistance or working).
Statistical Information About Families | Number and rate of families living in public or substandard housing and number who are homeless.
Statistical Information About Families | Number and rate of single-parent and two-parent families, by income level.
Statistical Information About Families | Number and rate of mothers in the work force, by income level.
Statistical Information About Families | Information on family preservation, including rates of child abuse and neglect, out-of-home placement of children, and percentage of families in the child welfare system who are preserved or reunited as a result of services.
Statistical Information About Families | Number of substance-abusing parents.
Statistical Information About Children and Adolescents | Number and rate of children who are abused and neglected.
Statistical Information About Children and Adolescents | Physical and mental health status of children, including number and rate of infant mortality deaths and numbers with low birth weight, developmental delay, learning disabilities, and emotional or behavioral problems.
| Rate of suicide among children and adolescents.
| Educational status and problems of children and adolescents, including school drop-out rates as well as rates of those proceeding to higher education or training.
| Violence and crime rates, including number of juvenile delinquents and homicides among youth.
| Numbers and rates of substance-abusing children and adolescents.
| Numbers and rates of unemployed teenagers and young adults.
Descriptive Information About Communities | The infrastructure of support for families in the community:
Descriptive Information About Communities | Supportive resources available for families as well as for whom and under what conditions they are available.
| Needs of families for whom there are no resources.
| Practices of education, housing, business, the judicial system, welfare, and other systems that help or hinder families in nurturing their children.
| Family-centered substance abuse prevention approaches and interventions:
| Those currently being implemented in the community, families receiving interventions, and conditions under which services are available (i.e., whether for all families, only high-risk families, or families in certain neighborhoods or housing areas).
| Unavailable or insufficiently available (yet necessary) resources and interventions.
| Organizations, groups, and institutions that have the potential to become partners with program developers in addressing a family-centered approach to prevent adolescent substance abuse.
NOTE: Whenever possible, these statistics should be gathered according to culture and ethnicity as well as geographic section or neighborhood of the community.

Identifying Community Resources In many cases, community resources to support families can be found outside of the more obvious formal and traditional sources such as schools, child welfare agencies, or mainline service organizations with a "substance abuse prevention" or "family" label. Examples are the following: In addition, it is important to identify more formal resources that offer family-centered programs, including parent training, in-home support services, and family therapy. These resources could include the following:; - School-based programs that offer parent training or education about substance abuse prevention.; - Child welfare agencies providing in-home support services to prevent separation of families or specialized foster parent training for children with special needs.; - Juvenile court programs that offer parent training or family therapy.; - Universities, community colleges, and health clinics that provide special clinical therapeutic services, parent training programs, or special demonstration or research programs.
  - Neighborhood leaders and informal networks.; - Religious organizations and churches.; - Community businesses.; - Cultural groups. | - Neighborhood drop-in programs.; - Child care and Head Start programs.; - Community centers.; - Literacy programs.

Table 4-3 illustrates possible ways to relate demographic information about the community to the risk and protective factors described in chapter 2. The relationships shown in this table are provided only as examples. Practitioners may find it difficult to identify demographic indicators for certain risk factors, such as those relating to family behavior, management, and parenting practices, or to assess the availability and adequacy of various protective resources. It is particularly helpful to hold community meetings and interviews to determine how families assess and respond to relevant problems, where they feel successful, and where they do not.

Table 4-3: Community and Family Data Organized by Risk and Protective Factors

Community and Family Indicators
Social Conditions | Risk Factors (i.e., Problems) | Protective Factors (i.e., Strengths)
Economic Status of Families | Number and rate of families living in poverty. | Number and rate of families living in poverty who have successfully raised children to be productive adults.
| | Number and rate of parents who have achieved economic self-sufficiency.
| | Availability of community programs to assist parents in achieving economic self-sufficiency.
Neighborhood Organization | Violence and crime rates, including rates of juvenile delinquency and homicide among youth. | Number of programs in high-risk communities that work with children and adolescents.
| Rate of suicide among children and adolescents. | Counseling resources available for children and adolescents.
| Rate of suicide among children and adolescents. | Number of neighborhoods that have banded together to make improvements.
| Rate of suicide among children and adolescents. | Availability of child care resources.
| Rate of suicide among children and adolescents. | Presence of housing opportunities for low-income families.
Social Behavior of Children and Adolescents | Numbers and rates of children and adolescents with diagnosed conduct and other problem behaviors. | Availability of therapy resources for children and families.
Social Behavior of Children and Adolescents | Violence and crime rates, including juvenile delinquency. | Availability of juvenile court rehabilitation resources.
Social Behavior of Children and Adolescents | Number and rate of children living in poverty. | Availability of alternative school programs and meaningful vocational education opportunities.
Social Behavior of Children and Adolescents | Number and rate of unemployment among young adults. | Number and rate of low-income children enrolled in programs for high achievers, gifted/talented programs.
Family Management and Parenting Practices | Number and rate of teenage parents. | Parent and family skills training programs available to all families and to high-risk families.
Family Management and Parenting Practices | Number and rate of working mothers. | Number of home visitation programs and other resources for new or young parents.
Family Management and Parenting Practices | | Availability and accessibility of parent self-help groups.
Family Behavior Concerning Substance Abuse | Number and rate of adult alcohol and drug abusers. | Availability of substance abuse prevention programs for families.
Family Behavior Concerning Substance Abuse | Number and rate of adolescent substance abusers (alcohol, tobacco, illicit drugs). | Availability of treatment programs for parents and children.
Family Behavior Concerning Substance Abuse | | Community laws and norms regarding adolescents' access to and abuse of substances.
Physical Maltreatment of Children | Rates of child abuse and out-of-home placement. | Availability and adequacy of family preservation programs.
Physical Maltreatment of Children | Rates of child abuse and out-of-home placement. | Percentage of children available for adoption who are adopted.
Physical Maltreatment of Children | Rates of child abuse and out-of-home placement. | Presence of child abuse prevention programs in the community.
Failure to Achieve in School | Number and rate of school dropouts. | Availability of special education services, tutoring, counseling, etc., for children and adolescents.
Failure to Achieve in School | Number and rate of students who fail required achievement tests or grades. | Availability of alternative education opportunities.
Failure to Achieve in School | Number and rate of runaway and homeless youth. | Availability of shelters and services for runaway and homeless youth.
Parental Monitoring | Number and rate of working mothers. | Availability of afterschool care for children of working parents.
Parental Monitoring | Number and rate of parents who participate in school events for parents, including conferences. | Flexibility of hours in school and other community programs.
Parental Monitoring | Number and rate of children in supervised afterschool programs. | Adequacy and safety of public transportation systems for adolescents.
Parental Monitoring | Number and rate of children who are at home alone after school, by age.
Parental Monitoring | Physical and mental health status of children, including those with developmental delay, learning disabilities, and emotional or behavioral problems.
Family Bonding | | Low-cost opportunities in communities for various family activities.
| | Availability of family support programs for all families and for high-risk families.
NOTE: Wherever possible, information on these indicators should be gathered according to culture and ethnicity as well as geographic or neighborhood distribution.

### Define the Problem

Once the assessment of the community's risk and protective factors is completed, practitioners can work with community partners to analyze the information collected. The purpose of this analysis is to identify the most prominent substance abuse problems among children and adolescents in the community and the risk and protective factors that are most clearly associated with these problems.

Substance abuse problems are often hidden or silent. Their extent may not be readily visible to the community, even when statistical and descriptive data are available. The risk and protective factors outlined in chapter 2 are valuable in determining whether there could be substance abuse in a community.

It is likely that several critical problems will be identified during the assessment phase. Priorities must therefore be established to determine which problems should be addressed first. A number of criteria can be used to determine these priorities, depending on the seriousness of the situation and the resources available (including the involvement of community partners). Thus, program developers initially may want to address an easier problem to build community support around a successful undertaking. In other circumstances, they may want to plan a more complex, multiple-problem strategy that will take full advantage of the resources and partners already in place. In all cases, the community should be solidly behind the criteria and the approach adopted.

Community mapping is an important tool for analyzing the scope of community problems. In the book Building Communities From the Inside Out, Kretzmann and McKnight (1993) describe a process for mapping community needs and assets. In a "Neighborhood Needs Map," they identify areas with negative community factors such as unemployment, gangs, child abuse, and lead poisoning. Each community can fill in the demographics and anecdotal information pertaining to these areas. In a "Community Assets Map," they delineate areas of community strengths, such as parks, cultural groups, businesses, and religious institutions. Community planners often overlook these neighborhood assets and their support for children and families.

Examples of the Neighborhood Needs Map and the Community Assets Map are shown in Figure 4-1. Program developers can transfer their findings from the community assessment to these maps to determine where they have sufficient information and knowledge about their community and where they need to look further.

Figure 4-1: Mapping Neighborhood Needs and Community Assets

Source: Kretzmann, J. P., & McKnight, J. L. (1993). Building communities from the inside out: A path toward finding and mobilizing a community's assets. Evanston, IL: Northwestern University, Center for Urban Affairs and Policy Research. Used with permission.

When analyzing information about community partners, it is also helpful to note the similarities and differences in agency and organizational missions, as well as varying perceptions about the community and its needs.

### Select a Target Population and a Prevention Approach

Practitioners, working with community and family collaborators, must decide how best to address an identified problem by selecting a target group of families to be served and a prevention approach that will meet their needs. In making these decisions, it is helpful to consider whether the problem has the greatest impact on all families in the community, or only on certain groups of families that are at above average risk for adolescent onset of substance abuse. The interests, needs, concerns, and issues expressed by families during the assessment process in response to various options should be taken into consideration. For example, some may hold the opinion that the problem should be treated as something everyone faces, thereby avoiding the labeling of families. High-risk families may either welcome or be resistant to extra support. The strengths families bring to addressing the problem may come to light during the assessment, as well as the extent to which community resources and collaborating partners are available to help with identifying target families, designing the intervention, and providing collateral support services and funding.

### Assess Characteristics of Target Families That Affect Participation

Research on the etiology of adolescent substance abuse and family-centered prevention interventions has demonstrated that broad demographic and anecdotal data are not sufficient for selecting a target population and planning an effective intervention. Rather, certain characteristics of target families need to be further explored to encourage their participation in the intervention.

Targeted Intervention Measures

Of the approaches reviewed in chapter 3, only one, family and parent training, encompasses universal, selective, and indicated preventive measures. The interventions grouped under this approach may address all families (universal measures), subpopulations of families with above average risk (selective measures), and/or specific families who have children with known, above-average risks (indicated measures). The other approaches, family in-home support and family therapy, are discussed in this guideline only for families with known risks (indicated preventive measures).

It is widely believed that engaging families in family-centered interventions is extremely difficult. Moreover, many practitioners believe that the greater the number of risk factors exhibited by families, the more difficult it is to elicit participation. However, it is apparent from the evidence presented in chapter 3, as well as from other etiological and intervention research, that it is possible to recruit and retain at-risk families in prevention programs, especially when planners take sufficient time to assess two particularly important areas: family cultural values, styles, and languages; and parents' beliefs about the risks to their children and their capacity to protect them.

Researchers and practitioners have used a variety of methods to involve potential participants in gathering valuable information about their cultures, values, and beliefs. Such strategies include focus groups, interviews with community leaders, community meetings with parents and adolescents, and surveys of the communities or neighborhoods in which families live (Spoth & Redmond, 1993; Spoth & Molgaard, 1993; Spoth, Ball, et al., 1996). In one program, registration forms for a work-site intervention were designed to gather basic information about families (Millman, 1992).

If resources are limited, practitioners can benefit from the relationships that have already been developed between the staff of community organizations and the families with whom they work. Examples of these organizations include health clinics, Head Start and other child development and child care programs, and visiting nurse and in-home services programs. The staff of these programs can be engaged as partners to implement some of the strategies for collecting information about parents' needs and aspirations. Senior citizens' groups and parent-teacher associations can be asked to help with the interviewing process as well.

#### Family Cultures and Values

Families from different cultures vary tremendously in their child-rearing and parenting values. Planners should define these values for the families and cultures they wish to serve, rather than operate from generalizations. Planners can begin by talking with local or neighborhood leaders, parents, grandparents, and teenagers who are from the same culture as the participants. The planners of the intervention can discuss what they are planning with these individuals and ask for suggestions on the best ways to learn about the culture.

There is a tremendous need to learn more about helping families from various cultures and adapting approaches that have been successful in meeting differing needs. The following paragraphs give examples of studies and practitioner-trainer experiences that demonstrate how the results of careful cultural assessment of target families can affect decisions about intervention planning.

Targeted Audiences

Most of the studies reviewed in chapter 3 target White families of mixed socioeconomic status. It is unknown whether these studies will apply in interventions with low-income families or families from other cultures, except for those studies that included these types of families in sufficient numbers in the original research.

Some cultures value the child and family as part of a total community that includes parents, other relatives, friends, and neighbors. These cultures underplay the values of individualism, individual achievement, or competitiveness. Interventions that overemphasize teaching parents how to promote the individual identities of their children may fail in families from these cultures because they counter the esteemed norms of the cultural community. For example, many Native American families want their children to learn patterns of communication and problem solving that fit with their tribal history, family and community patterns of relationships, and tradition of honoring elders. For these families, interventions should focus on enhancing family functioning to promote the cohesiveness of the tribal group (Indian Health Service, 1995; Northwest Indian Child Welfare Association, 1993).

One study of bicultural effectiveness training for Cuban-American families demonstrated the importance of addressing intergenerational conflict as a critical part of family therapy. Teaching families how to identify and resolve these culturally based conflicts between older parents and grandparents and younger adolescents helped families regain their familial strengths to support adolescents (Szapocznik, Santisteban, Kurtines, Perez-Vidal, & Hervis, 1983).

In some cultures, parents' capacities to teach their children to cope with racial prejudice can affect the youths' ability to adopt prosocial behaviors. By understanding the environment in which the family exists, practitioners can "market" the intervention according to the family's needs (Santisteban et al., 1995).

Observers of African-American families in various settings have noted the protective factors afforded by strong kinship bonds; a willingness to open households to others, especially children; and a strong religious orientation (Boyd-Franklin, 1990). Practitioners can look for these strengths during family and community assessments and design interventions that build on them.

Techniques for disciplining children among various cultural groups can influence the ways in which families respond to specific types of interventions. In one intervention that served African-American families (Myers et al., 1990), the authors found it necessary to design specific discipline strategies that translated "traditional Black discipline" into "modern Black discipline," focusing on "appealing to children's minds, not behinds."

#### Parental Attitudes and Beliefs

Planners can benefit from an assessment of parents' beliefs about the susceptibility of their children to substance abuse and their ability to prevent it. These beliefs may be associated with the socioeconomic status of the target population and may affect the ability of the program to meet this population's needs. Parents differ in their beliefs about what can be accomplished to protect their children through parenting practices and how this goal should be achieved. For example, many parents may not be aware of the prevalence and severity of the problem of adolescent substance abuse and the extent to which they can influence their adolescents' behavior in this regard (Spoth & Conroy, 1993). Characteristics such as income and education of parents (demographics that can be obtained during assessment) are particularly important clues for planners in understanding the beliefs and attitudes of the identified target population (Spoth & Redmond, 1995; Spoth et al., in press-a).

Spoth and his colleagues (Spoth & Conroy, 1993; Spoth et al., 1997; Spoth, Redmond, Yoo, & Dodge, 1993) conducted studies on protective parenting behaviors among families across the socioeconomic spectrum. Factors including parents' income, educational attainment, and gender can influence whether and how they seek formal sources of help, such as counseling and skills training programs, and informal sources of help, such as reading articles and books about raising children and discussing parenting issues with friends and relatives. Additionally, in a prospective study of predictors of actual enrollment in family skills training programs, education level emerged as a relatively strong predictor of enrollment (Spoth et al., in press-a, in press-b).

Studies of rural families indicated that these parents believed they could prevent adolescent substance use through their parenting behavior and tended to be fairly active in their parenting (Spoth & Conroy, 1993; Spoth et al., 1993). These parents, however, tended not to seek formal support to prevent substance abuse by their children, even though community demographics indicated the existence of a significant adolescent substance abuse problem. When these families sought help, it was through personal and informal contacts rather than professional sources or parent or family skills training (Spoth & Conroy, 1993).

Practitioners should recognize that some parents do not consider engaging in parenting skills training an appropriate or valid parenting practice. These parents may never want to enroll in a parenting program, no matter how it is presented. It is important to find out who these parents are. Then, efforts can be made to acquaint them with the severity of adolescent problem behaviors so that they can appreciate the need for delivery of an intervention (Spoth & Conroy, 1993).

### Establish a Process for Involving Families and Community Partners

The key product of assessment, as outlined in the previous paragraphs, consists of a number of steps geared toward gathering and analyzing information about the scope of the problem to be addressed, the target population, and the best approach to meet the needs of the community. Woven into each of these steps is the concept of involving community organizations and target populations. While the product outcome of assessment consists of a quantifiable end result (demographic profiles, a description of the problem, and the approach selected to address it), the process outcome results in the participation of the community in the development of that result.

If successful, the process outcome of assessment will accomplish the following:

- Inclusion of the primary target population in the collection and analysis of information about the problem and the population it primarily affects.
- Identification of the common goals and missions of community organizations and agencies.
- Participation of community partners in the analysis and definition of the community's substance abuse problems.
- Assessment of family cultural values and parents' attitudes and beliefs about the substance abuse problem and their own capacities to affect it.

Addressing Intrapopulation Differences

Beyond addressing variations among cultures, practitioners should recognize that families within target populations are not homogeneous. A recently published study (Spoth, Ball, et al., 1996) illustrates how families from a seemingly homogeneous population sharing a common culture and geography (White, rural, Midwestern) differed by familial interest and readiness to participate in family-centered programs. The authors conducted a survey of the parents, requesting them to rank the importance of program design features, such as program duration, meeting length, program focus and format, and facilitator background. (See Spoth and Redmond [1993] for a description of the consumer research methods that can be used for this type of study.) When the responses were analyzed, three clusters of families emerged. Preferences for specific program features varied among these clusters.

The first cluster of parents expressed interest in an intervention involving minimal effort and showed a very limited preference for specific program content. The researchers concluded that it might be difficult to persuade these families to participate and that they might require simple, frequently repeated, and well-recognized messages about the intervention, including references to intervention features of importance to them. A second cluster of parents indicated interest in an intervention requiring more effort, but focused on substance abuse prevention. A third cluster was interested in an intervention requiring moderate effort and focusing on family communication skills. Had the authors not conducted this survey, they might have assumed that these families, who shared basic sociodemographic characteristics of a relatively homogeneous population, all would have responded similarly to the offered intervention.

The assessment processes described are essential in laying the foundation for community endorsement and commitment of resources and ongoing sharing of responsibility for planning and implementation. Family participation in the intervention is also critical. Practitioners should attend both to the processes and the products of assessment to achieve desired results from family-centered prevention interventions.

## The Planning Stage

The desired outcome of the planning phase is an intervention design based on the results of the assessment that will meet the needs of the target families. The primary tools for developing this design are the information that was gathered and decisions made during the assessment process, including the following:

- The data gathered on families and the community, organized by risk and protective factors.
- A definition of the substance abuse problem to be addressed.
- The target families most affected by the problem.
- The most appropriate approach to meet the needs of the target families.
- The characteristics of the target families that will influence their participation.
- The community partners who can help with the project.

The program plan should include goals and objectives that describe the action or change expected and the extent of change anticipated, as well as the structure and activities of the intervention. Activities should be chosen to meet the stated goals and objectives and should be carefully described to provide a protocol for intervention delivery. To assist in completing these tasks, planners often establish a planning group that includes target families and is representative of the community. This planning group can help to develop the community collaboration and resources needed to support the project and can provide a forum for sharing the intervention plans with the community at large and with potential participants.

Etiological and intervention research on family-centered interventions has focused specifically on two critical areas of planning (which are discussed in the following sections): (1) planning partnerships with parents and community collaborators and (2) planning for recruitment and participation.

### Develop Partnerships With Parents

Traditionally, program developers, trainers, social workers, and psychologists have determined families' needs and what is best for them based on their own experiences and observations or on a particular theory about families. With this approach, however, families rarely have an opportunity to express their ideas about their own needs or to collaborate in the development of a project in which they can be involved. More important, however, in such situations, parents do not participate in decisions about their own children, resulting in a loss of a wealth of knowledge and expertise, and a missed opportunity to build the intervention on these strengths.

As there is now a greater appreciation of this issue by researchers and practitioners, new research findings and practices are exploring ways to share expertise with families so that they can become partners in the planning and evaluation of interventions. The following strategies are particularly important for achieving optimal effectiveness of an intervention:

- Building opportunities for parents, rather than imposing requirements.
- Listening and responding to parents' goals and expectations, rather than defining them.
- Increasing parents' feelings of self-efficacy and self-control.
- Designing program options to accommodate possible differences within family populations that appear homogeneous.
- Designing interventions that build on and integrate families' social and support networks.

Research on parents' readiness to change has emphasized the significance of forming partnerships with parents in developing prevention interventions. Parents who are open to self-development through a family-centered intervention tend to be those who have already benefitted from professional help. The stronger their sense that they can effect change for the better, the more likely they are to be ready to change (Spoth et al., 1995). Socioeconomic status also affects parental self-efficacy: In particular, the more highly educated parents are, the more likely they are to feel that they can bring about change, but such feeling is tempered by a corresponding increase in perceived susceptibility to problems (Spoth et al., 1993).

### Develop Relationships With Community Partners

In designing family-centered interventions, the development of collaborative relationships with other community service providers and family support groups can provide a safety net of services to meet the basic needs of participating families. Continued planning for such collaboration during the design of an intervention will help providers understand the underlying concepts and principles of a family-centered intervention and contribute to an informed consensus on shared goals.

Weiss (1995) noted that the effectiveness of family-centered programs depends on "the availability and quality of other resources that can support and enrich family life, such as child care and after school programs, recreational activities, and cultural events; services that can meet the needs and concerns of children and families, including housing, jobs, and health care; and the capacity of programs to connect with these resources" (italics added).

Partnership Planning Strategies

Examples of partnership planning strategies can be found in two of the studies reviewed in chapter 3: Felner et al. (1994) is an example of a work-site parent training intervention, and the Families in Focus practice case is an example of a family skills training intervention.

Effective community collaboration integrates the perspectives of multiple individuals and organizations who have an interest in substance abuse problems in the community. Collaborating parties participate in finding solutions to those problems. Involvement of these stakeholders leads to a program design that includes community resources and concerns. Figure 4-1, Mapping Neighborhood Needs and Community Assets, can be used to identify and expand the community partnership network. In completing each section of the map, it is helpful to focus first on those organizations that have the most positive and mutually collaborative relationships, and then add respected organizations that have this potential. These organizations can form a core collaborating group to assist with the development and financing of the project.

Developing Collaborative Relationships

Some examples of interventions summarized in chapter 3 that developed collaborative relationships with other organizations include the research studies of Felner et al. (1994), Catalano, Haggerty, Gainey, Hoppe, & the Social Development Research Group (1995), Henggeler et al. (1986), Mann, Borduin, Henggeler, & Blaske (1990), Spoth et al. (1995), Spoth et al. (in press-a, in press-b), as well as the practice cases of the Kansas Family Initiative, Creating Lasting Impressions, and Families in Focus. In addition, several family-centered prevention projects have employed the Cooperative Extension Network in every State.

Facilitating Partnerships

A community action agency in Iowa, while planning a family development program, realized that to be effective it had to enlarge its effort to include "facilitating partnerships" within the larger network of community agencies. Over a period of several years, this agency established a 47-member, cross-disciplinary "community academy." The academy of agencies increased its assessment of the status of families to a five-county area (Deutelbaum, 1992).

Forming viable partnerships with one or more institutions or agencies in other domains, such as schools, religious institutions, work sites, cultures, or neighborhoods, cannot be accomplished by patching together separate projects with individual funding streams under one general heading and calling it a "multifocused strategy." Rather, it is essential that intervention activities be unified under one set of goals and outcomes and one planning structure. Although this effort is time consuming, the process results in shared ownership of the vision and goals of the project, consensus on outcomes, and more effective use of available resources, including funding.

### Identify Barriers to Recruitment and Participation

A critical aspect of the planning stage is identifying potential barriers to recruitment and participation of the targeted population. These barriers may have to do with the ways in which an intervention is presented to the target population or with real or perceived obstacles preventing their participation.

#### Barriers to Recruitment

The way in which program developers first present and describe a family-centered intervention can influence parents' interest in the program and their willingness to participate in it. For example, although planners may want to provide indicated prevention measures for specific families who are identified as at risk, they may find that widening the focus of the program to include families who are from at-risk populations may make participation more appealing. Broadening the focus of a program in this way may help to avoid having participants feel as though they are being labeled "bad" parents (Hawkins et al., 1987). In other cases, some parents may resent being asked to participate in an event labeled "parent training" but may respond positively to a "child management skills program" (Lochman & Wells, 1996). The following paragraphs describe additional examples demonstrating how planners overcame barriers to recruitment.

Multifocused Prevention Strategies

Some examples of studies described in chapter 3 that illustrate a multifocused strategy are the research studies of Catalano et al. (1995), Hawkins et al. (1992), and Henggeler et al. (1986) and the practice cases Creating Lasting Impressions, the Parenting for Prevention program, and Families and Schools Together (FAST).

The parent training program of Felner et al. (1994), reviewed in chapter 3, was conducted at a large corporate work site and was offered to all employees. Recruitment was carried out through several mechanisms, the most successful of which included word of mouth, invitations from friends, and a registration booth.

In Fast Track, another family-centered parent training intervention, staff conducted telephone interviews and home visits with parents to learn more about their interests, circumstances, and views before suggesting participation in an intervention. This recruitment approach also supported a partnership with families and strengthened the interrelationship between family and school settings (McMahon, Slough, & Conduct Problems Prevention Research Group, 1996).

A group of family therapy researchers found that resistance to participation in family therapy interventions had to be addressed during the very first contact with the family, rather than waiting for the first therapy session (Szapocznik et al., 1988; Santisteban et al., 1996). Resistance to participation was so strongly intertwined with the reasons why the family needed therapy that the therapist had to address the resistance immediately, during initial engagement with the family.

#### Barriers to Participation

Research has demonstrated a number of real or perceived barriers that prevent participation by parents in interventions. Identification of these barriers during the planning stage allows them to be addressed in the design and budget for the intervention. As discussed in the section on assessment, practitioners can assess barriers by conducting focus groups, surveys, or interviews during either the assessment or planning stages. Some of the common barriers are discussed below.

##### Lack of Awareness of Benefits of an Intervention

Spoth and Redmond (1995) tested a model of motivational factors influencing parents' inclination to enroll in a parenting intervention in the rural Midwest. They found the perceived benefits of the intervention (perceptions directly influenced by the perceived severity of the problems and the perceived susceptibility of adolescents to the problems) were the strongest predictors of the parents' inclination to enroll.

##### Cultural Barriers

Many families do not trust or respond to projects that are designed and led by persons outside of or unfamiliar with their culture. These families may be concerned about being negatively singled out and may believe the project's values do not reflect those of their culture. In addition, because of issues associated with immigration and acculturation and the distress that often accompanies these experiences, many immigrant families need special assistance to rebuild and develop social support systems and overcome language barriers.

Addressing Cultural Barriers

Examples of studies reviewed in chapter 3 that address cultural barriers are those of Aktan, Kumpfer, & Turner (1996), Kumpfer, Turner, & Palmer (1991), Myers et al. (1990), Santisteban et al. (1995), and Szapocznik et al. (1989).

Cultural barriers to participation can be overcome by consulting and involving leaders in the community who are from the target families' cultures in the design, interpretation, and presentation of the intervention. These individuals can include teachers, businesspeople, nurses, and grandparents. In addition, the intervention must be closely allied with the most accessible resources to support the service needs of families, especially those resources available within local neighborhoods and communities.

##### Lack of Support for Basic Needs

Many families cannot participate in intervention programs because they must attend to crises with housing, medical care, finances, employment, or other basic needs. In addition, it is common to find considerable mistrust and hostility among families that have been involved with multiple systems such as child welfare, juvenile justice, and public assistance programs. Intervention planners are increasingly realizing that to involve these families they must first, or simultaneously, assist them with these crises. The prevention approach of in-home support services is particularly effective in addressing these barriers.

Addressing Basic Needs

Examples of studies summarized in chapter 3 that address support for basic needs are that of Catalano et al. (1995) as well as the practice cases Creating Lasting Impressions, Families in Focus, and the FAST program.

Additionally, collaborative efforts with community service providers can be developed as part of the intervention. Referral systems that emphasize one point of coordination and service management avoid pulling families in many directions because of competing requirements. Providing support for basic needs helps strengthen and reinforce the family's self-control and self-efficacy.

##### Negative Views of Prevention Approaches

Many families find any intervention to be intrusive, particularly if their behavior is being assessed (especially by videotaping); if they perceive interference with their parental rights, responsibilities, and authority (i.e., someone interfering with the way their children think and act); or if their participation is or seems mandated rather than voluntary. Family therapy, for example, is often viewed as "mysterious" and out of the parents' control. Others misunderstand terms in parent training such as "contracting," which may appear to promote equality between children and parents and thus reduce parental authority. In addition, some parents think they can handle problems effectively without programs (Spoth, Redmond, et al., 1996).

One study designed to engage adolescent substance abusers and families in treatment found that adolescents' unwillingness to participate could be a major barrier to successful treatment. It also found that fathers were less interested than mothers in attending program sessions and that mothers' decisions about whether to participate were influenced by the fathers' interest. From this study, it appears that any family member who refuses to participate can influence the entire family's participation (Szapocznik et al., 1988). Another study (Families and Schools Together) found that the assessment mechanisms asked inappropriate questions, forced parents to compare their children with other children, or to view their children negatively.

##### Work-Site Barriers

Barriers may become apparent when interventions are offered at parents' work sites. For example, scheduling an intervention at lunchtime may not work because many parents use lunch hours to attend to other priorities. Further, employers may not allow long lunch hours or flexible schedules to accommodate employee attendance at the intervention (Millman, 1992). (See the study of Felner et al. [1994], a work-site intervention described in chapter 3.)

##### Characteristics and Settings of the Intervention

At a minimum, interventions should be carried out in accessible, comfortable settings located in the communities of the participating families. Appropriate settings include schools, churches, community centers, homes, and housing projects. Familiarity with the needs and preferences of the family populations served allows facilitators to provide the intervention in settings and schedules comfortable and convenient for participants.

Addressing Negative Views

Examples of studies described in chapter 3 that address negative views toward interventions are those of Gordon, Arbuthnot, Gustafson, & McGreen (1988), Kumpfer and DeMarsh (1987), Spoth et al. (1995), and the practice study on the FAST program.

Even when interventions are offered at times most convenient for target families as a whole, studies show that substantial numbers of potential participants may still be unable to attend. Consequently, practitioners should consider giving participants multiple scheduling options, thus accommodating the greatest number of families.

Among the program characteristics that commonly affect participant attendance and retention are the following:

- Duration of the program.
- Length, time, frequency, and proximity of meetings.
- Access to transportation, child care, and meals.
- Program focus, format, and endorsements.
- Expertise and background of facilitators.

If these factors do not match the desires, needs, and expectations of the targeted families, these families may not participate or may drop out of the intervention. Although these issues involve implementation steps, they must be addressed during the planning stage to ensure that sponsoring organizations can provide the necessary financial resources and facilities to meet the needs of the identified target population.

### Ensure Appropriateness of the Intervention to the Needs of Targeted Children

To achieve maximum benefits, an intervention must be appropriate for the age, gender, and developmental stage of the children for whom it is intended. For example, research demonstrates that traditional family therapy does not work well with young children, who are unable to communicate in this setting on an equal footing with parents and older children. Several interventions described in chapter 3 appropriately include young children through family play therapy - i.e., teaching parents how to improve their parenting skills through supervised participation and interaction with their children while they are playing (e.g., Forehand & Long, 1988; McMahon et al., 1981; Springer, Phillips, Phillips, Cannady, & Kerst-Harris, 1992).

## Delivery of the Intervention

If the issues identified during the planning stage have been attended to properly, all major decisions concerning the intervention will have been made by the time planners reach the delivery stage. The task is then to carry out the intervention as planned. Effective implementation, however, requires careful attention to the details of the intervention as it unfolds and a capacity to adjust elements of the delivery in response to participant and facilitator feedback. Delivery issues for family-centered interventions include hiring, support, and training of staff and facilitators, providing support in the best way to parents as partners in delivering of the intervention, and implementing strategies to monitor and retain participants in the program.

Intervention Characteristics and Settings

Interventions discussed in chapter 3 that specifically address characteristics and settings of interventions are the research studies of Catalano et al. (1995), Felner et al. (1994), Gordon et al. (1988), Mann et al. (1990), McPherson, McDonald, & Ryer (1983), and Myers et al. (1990); and the practice cases Creating Lasting Impressions and the FAST program.

### Weigh Staffing Considerations

There is widespread agreement among researchers and practitioners that effective staffing is crucial to the success of a family-centered intervention. Every aspect of staffing deserves close attention.

#### Hiring Criteria for Staff

The following three requirements of staff are equally important to the success of the project:

1. Expertise and training - For example, facilitators or therapists should be trained in child and family development, substance abuse prevention, the interrelationships of risk mechanisms and protective factors, and adult education and group facilitation skills.
2. Effective interpersonal skills - These include flexibility, positive attitudes about children, and a capacity to be comfortable with and respectful of all kinds of people.
3. Commitment - Individuals should believe in the efficacy of and have a commitment to the intervention project.

Hiring and training qualified receptionists and secretaries should be a high priority because they often have first contact with parents. Since their interpersonal skills and commitment to the project are critical, they will need training to ensure that they understand the project and have the skills to be supportive of families.

It is often difficult to ascertain the extent of expertise, interpersonal skills, and commitment of a potential hire, even after careful review of paper qualifications, interviews, and recommendations. Resources that can assist practitioners in the hiring process are the publications Effective Hiring Practices: A Look at Personality, Attitudes, and Skills (Chalifour, 1993) and Helping Children Affected by Substance Abuse: A Manual for the Head Start Management Team (Head Start Bureau, 1994).

#### Criteria for Facilitators and Therapists

Research has demonstrated that parents have very specific expectations of intervention facilitators (those who interact directly with them in carrying out the program), whether they are social workers providing in-home support services, psychologists providing family therapy, or trainers. These expectations are not always obvious. They are often closely related to parents' views of the efficacy of prevention efforts and their views of themselves. Depending on desired outcomes, parents have definite preferences concerning facilitator's knowledge, education, and resources. As discussed throughout this chapter, the views and preferences of the target families are important considerations in the planning of an intervention (Spoth & Redmond, 1993, 1996; Spoth, Ball, et al., 1996).

Whenever funds allow, using cotrainers or leaders allows various leadership styles, levels of expertise, and male-female training pairs to be offered to participants. Coleaders have the advantage of playing different roles during training, such as "the observer" and "the leader" (Lochman & Wells, 1996).

Addressing Facilitator Preparation

Many of the intervention studies described in chapter 3 provide descriptions of techniques for preparing facilitators (whether as trainers or therapists), particularly in cases where the facilitators were graduate students (Barton, Alexander, Waldron, Turner, & Warburton, 1985; Wolchik et al., 1993), volunteers (Creating Lasting Impressions; Families in Focus; Kansas Family Initiative), or parent graduates (FAST; Guerney & Wolfgang, 1981).

Thorough training of facilitator teams enhances the effective delivery of an intervention. Kumpfer, Molgaard, & Spoth (1996) found that it is more effective to conduct facilitator training in two sessions over at least 2 days. The first session can include a basic presentation of the materials, while the second session can be used to give trainers structured opportunities to use the materials in role-playing exercises.

#### Support for Staff

Working with stressed or troubled families places an enormous emotional burden on staff members, who need tremendous support. This support is especially important if the intervention is large in scope or involves hiring paraprofessionals and parents. Providing staff with a variety of support systems enhances their ability to perform effectively and helps avoid burnout. The following methods can be used to facilitate staff support in the implementation of an intervention.

Team Building. This approach includes strategies for developing team approaches to program development and delivery, such as defining and understanding each others' roles and responsibilities, managing conflict, making decisions, and communicating effectively.

Facilitator Meetings. These meetings provide opportunities for facilitators to support each other by discussing problems and exchanging ideas and experiences.

Staff Support Networks. These personal referral resources for staff (particularly for staff paraprofessionals and parents) help with personal and family problems that may emerge in the staff's lives while they are participating in leadership of the intervention.

Participant Referral Network. A collaboration and referral network for facilitators responds to crises and special needs of participating families (see the sections Collect Family and Community Data and Organize by Risk and Protective Factors and Develop Relationships With Community Partners in this chapter).

### Deliver the Intervention in a Partnering Relationship With Parents

Continuing to share expertise and decisionmaking responsibility with parents during the implementation stage helps them to become full partners in the delivery of the intervention, rather than just recipients of a service. The extent to which the partner relationship with parents is maintained depends heavily on the facilitators' understanding of this concept and commitment to making it a reality. Although some professionals have begun to provide interventions that enter into a partnering relationship with parents, this type of relationship may be inconsistent with the training of many professionals in social work, therapy, psychology, and teaching. Most professionals in these fields have been trained to view the persons they serve as clients or patients whose care they manage and for whom they have "the answer" or solution. To overcome these biases and develop self-awareness about behavior, the concept of partnership must be frequently revisited in staff training, supervision, and communication. Several strategies to assist in these processes are described in the following paragraphs.

#### Active Involvement of Parents

Consistently involving parents in all aspects of intervention delivery reinforces partnership roles. Parents can serve as language or cultural translators or help with logistics and food. Some parents can be hired as support staff or paraprofessional trainers. Finally, participation by parents in some of the intervention's parent-child interactions, which draw upon parents' knowledge of their children to evoke change, can be viewed as in-service training. This encourages parents to view themselves as partners in the training process, rather than just recipients (McMahon et al., 1996).

#### Dialog Between Parents and Facilitators

The delivery style of facilitators has a significant impact on the partnership with parents. Facilitators can involve parents through several interactive processes (Cochran & Woolever, 1983; Hawkins et al., 1987; Lochman & Wells, 1996; Prinz & Miller, 1996). These include the following:

- Asking parents about their parenting styles, the strategies they are currently using, and which ones they would like to improve.
- Building on what parents are already doing that has elements of success, rather than pointing out failures.
- Avoiding the suggestion or implication that parents must do things "your way" and stop doing them "their way"; giving alternatives and encouraging them to try out suggestions and report on the results.
- Helping parents feel valued and competent by highlighting their progress, validating their efforts, and celebrating their successes - e.g., for persisting in their efforts or for achieving mastery of skills and knowledge.
- Paying attention to adjustments in delivery of the intervention that will increase parental control over their own behavior and their confidence with the children.

#### Use of Parent "Graduates" From the Program

Parents who have successfully completed the intervention (parent "graduates") can assist practitioners in recruitment and in contacting dropouts. They can also serve as consultants in the planning and design stages of the project. Parents who are committed to the intervention can be a strong motivating force and may prove to be the most effective communicators with new parents and the most helpful in supporting retention of these new parents in the project.

### Develop Strategies To Monitor and Retain Participants

Even with effective groundwork laid for recruiting families and ensuring their ongoing participation, as described in the assessment and planning sections of this chapter, retaining families in a project can prove difficult. Several strategies, described in the following paragraphs, have been shown to be particularly helpful in encouraging parents to continue participation and in determining the reasons why parents may drop out.

#### Incentives for Participation

Providing incentives for parents who participate in the program can be an effective way to recruit and retain them. Examples of incentives include the following:

- Free transportation and child care.
- Snacks or meals served during intervention activities.
- Free coupons for food or video rentals.
- "Graduation" gifts.
- Parties or family outings.
- Access to clothing or food banks.
- Referral services for legal, medical, housing, and financial aid.

Addressing Partnering With Parents

The FAST program, described in chapter 3, is one intervention that uses parent graduates. Other interventions discussed in chapter 3 that address the issue of partnering with parents are those of McPherson et al. (1983) and the Families in Focus program.

Cash incentives may be useful in some instances. Alternatively, if resources are available, program staff may prefer to provide goods or coupons to parents who come to the initial session, with a bonus incentive of goods for completion of all sessions (Kumpfer et al., 1996). Information about the incentives offered should be included in recruitment literature, advertisements, and announcements, giving full credit to those who are donating services or collaborating with the program. This also will strengthen community ownership and involvement with the project.

#### Addressing Nonparticipation

Despite the best planning efforts, some participants will drop out for a number of reasons. These include unexpected crises, forgetting, feelings of incompetence and hostility, inadequacies of the facilitator, or disappointment with the direction of the project (Office for Substance Abuse Prevention, 1991). As information is gathered about participants missing a session or dropping out, facilitators and supervisors should meet to review what they have learned and to consider adjustments in the content and delivery of the program.

Addressing Incentives

Some interventions discussed in chapter 3 that include incentives are those of Catalano et al. (1995), Felner et al. (1994), and Myers et al. (1990) and the Parenting for Prevention and FAST programs.

The most effective way to understand why participants drop out or attend infrequently is to talk with them individually, preferably in person but, if necessary, by phone. Participants who miss a session should be contacted and told that they were missed. The content of the last session they attended should be discussed to determine whether something happened to disappoint or offend them. An attempt should be made to determine, in a supportive and nonintrusive manner (perhaps using a parent cofacilitator), whether a crisis has occurred or whether the missing participant needs additional support to attend. Even if parents are not willing to share their reasons for missing sessions, the caring interest and interaction may draw them back to the next session.

#### Referral Network for Basic Support

A referral network for basic support will emerge from the community collaboration work conducted during the planning phase. This network should include referrals for housing, food, job placement, and other services that are not directly available through the intervention. Although this may seem like a straightforward task, the referral process is likely to be the first system to break down unless careful attention is paid to its development and maintenance. Community services are often fragmented, and agencies may have barriers built into their funding requirements that prevent them from working effectively together. In addition, service agencies may compete for families, refuse to serve certain families, or quarrel among themselves.

Participant Retention Strategies

Examples of techniques for retaining participants can be found in Berry (1992), Catalano et al. (1995), Felner et al. (1994), Kumpfer and DeMarsh (1987), and the Creating Lasting Impressions program. These studies are discussed in chapter 3.

To maintain an effective referral service, the organization sponsoring the intervention must be thoroughly acquainted with the services provided by each agency; the people who receive these services; the rules of eligibility and participation for each agency; their hours of operation and their locations (including how to get clients there by public transportation); and feedback from families about how effectively these services meet their needs. The following steps can help develop and maintain an effective referral network:

- Develop or obtain a community referral directory with pertinent information about each agency and provide it to each staff person. Make the directories available for participants at a resource table and make announcements about them during training.
- Survey parents about the effectiveness of service agencies, especially those that are most commonly used. Seek out groups of parents who use them, such as parents from schools or churches in low-income communities. Find out what is needed to make the most effective use of the referral service.
- Train all facilitators in the referral system and the services available.
- Follow up on all referrals to make sure they are completed by parents, to ascertain whether services were provided, and to uncover any problems.
- Meet regularly with agencies in the referral system to exchange mutual feedback about issues and problems and to develop more effective ways of serving the intervention participants.

Although not all parents will need referral support, relevant services should be in place so that support can be provided as the need of individual families arises.

## The Evaluation Stage

Two basic types of evaluations can be considered by practitioners, depending on the purpose of the evaluation and how the results will be used. For each type of evaluation, a range of evaluation activities can be used to determine whether the project effectively helped the target families. A process evaluation reviews the way in which project activities are carried out. Practitioners use process evaluation during the implementation stage of the intervention to monitor progress and determine whether the project is being run in a manner likely to achieve specified goals and objectives. A summative or outcome evaluation examines the degree to which the interventions achieved the specified goals and objectives. Sponsoring organizations often require summative evaluations to determine whether to obtain further financial support to continue or expand the interventions. In addition, such evaluation is required to justify continuation of a project or show that the project achieved specified outcomes.

Practitioners of family-centered prevention programs may believe that they do not have the resources, time, or appropriate expertise to conduct evaluation activities. Others may believe that evaluations are useless or fear that the results will be harmful in some way to the sponsoring organization's program. As a result, practitioners often lose the opportunity to gain objective information about the success of their undertakings. With some careful thought and consultant expertise, however, it is possible to design evaluations that will yield valuable information about implementation of the intervention and attainment of outcomes.

To be most effective, evaluation activities must be planned very early in the program development process, such as during the planning stage. Particular attention should be paid to the following five evaluation activities:

1. Consulting with evaluation experts who have experience in evaluating family-centered projects.
2. Developing data sources available from and procedures appropriate to family-based approaches.
3. Continuing the involvement of participants, staff, and other stakeholders in the evaluation process.
4. Considering a variety of evaluation methods and measures that can be used easily with family-centered projects.
5. Considering cost factors in relationship to beneficial outcomes for families at various degrees of risk.

Each of these activities is discussed in the following sections.

### Consult With Evaluation Experts

Many organizations have access to an expert who can be consulted on the planning and design of an evaluation. Universities, colleges, and community college systems often have departments with this expertise, such as those of child and family development, social work, psychology, public health, and social ecology. Depending on the available financial and personnel resources, project staff could hire a faculty member to conduct the entire evaluation or could persuade the institution to allow a graduate student to conduct the evaluation as part of a dissertation. Alternatively, the organization could request in-kind or free evaluation consultation from a qualified collaborating organization in the community.

Several factors should be taken into account when selecting an evaluation consultant. First, to ensure an objective evaluation, the evaluator should be independent of the management and implementation of the program. Otherwise, the project design could be altered by project staff to obtain positive outcomes. Second, the evaluator should have an understanding of and a commitment to critical project concepts, such as creating partnerships with parents and involving community stakeholders in the assessment and planning processes. Third, an evaluator should be willing and able to take costs into account and to design an evaluation that will meet both the needs and the budget of the project. Finally, the evaluator should be willing to participate in project development to understand the project's objectives, anticipated problems, and staff attitudes and practices. Although the evaluator should remain objective and independent, this person also can provide valuable feedback about aspects of the design and implementation of the program to improve its compatibility with evaluation methodologies.

### Develop Appropriate Data Sources and Procedures

Practitioners most often use process evaluation to ensure that a project is implemented as planned. With the information gathered through this process, practitioners can monitor the implementation process as it unfolds and make midcourse corrections for a project that may not be achieving specified goals. Practitioners must realize, however, that midcourse corrections can interfere with summative or outcomes evaluation results. The following are data sources for process evaluations of family-centered prevention interventions:

- Assessment strategies.
- Recruitment procedures and success rate.
- Participant attendance at sessions.
- Participant feedback about process and content of sessions.
- Therapist's or facilitator's logs of sessions.
- Feedback from participants who did not complete the program.
- List of collaborating agencies.
- Number of participants served.

For each of these data sources, program developers can review the preceding sections of this chapter to identify questions they wish to answer as the project progresses. Gathering information from these sources can assist in determining the degree to which activities, resources, services, and environment facilitated achievement of the intervention's objectives; the appropriateness of activities for the target families; and the consistency of the project's implementation in comparison with what was planned.

For example, practitioners may want to implement several recruitment strategies and monitor resulting success rates during the initial phase of recruitment. They could then use the most successful strategy to complete the recruitment process.

### Consider a Variety of Methods and Measures To Evaluate Outcomes

Many program planners consider just one or two commonly used evaluation methods, such as pretests and posttests, which may not give useful or adequate information about project outcomes. Other evaluation methods, however, can allow program planners to determine whether the project achieved its stated goals and objectives.

Many researchers believe that the ideal evaluation design for determining whether an intervention has achieved its stated outcomes is an experimental or sophisticated quasi-experimental design. These types of evaluation design require the use of control or comparison groups, methods that are expensive and complicated for many practitioners to carry out with available resources. Furthermore, such designs may place sponsoring organizations in the difficult position of denying services or support to some families who would benefit from them, a practice that may be decried by families who are participating in the planning stage.

It is possible, however, to learn a great deal about the outcomes of an intervention without using these research strategies. Practitioners can use one of two simple methods of evaluation to determine whether the observed outcomes resulted from the intervention. Either of the following methods will be inexpensive and will allow more family participation in the evaluation process than an experimental or quasi-experimental design:

1. Assessment of participants regarding specified family and/or child behaviors before and after intervention delivery.
2. Comparison of the specified behaviors of participants who have completed the program with those of participants who are on a waiting list, often referred to as "wait-list controls."

When carefully and rigorously employing these evaluation methods, practitioners can use one or more of the following measures to assess the progress of participants. The choice of measures to use depends on the specified outcomes and the intervention used. Many of the studies described in chapter 3 used examples of these measures, which researchers tested for reliability and validity:

- Observation of the participants practicing what they learned in everyday settings at home.
- Exercises in which participants demonstrate what they learned in simulated or clinical settings with their children.
- Role-playing activities.
- Third-party observations of the intervention.
- Structured interviews with the parents.

Whenever possible, practitioners should use measures that have proven to be reliable and valid. Measures that are reliable will produce the same result (score) when applied two or more times. For example, if parents are interviewed twice within a week regarding their child's behavior problems, a reliable interview will produce very similar reports about the problems. Measures that are valid actually assess what the evaluator wants to measure. Thus, a valid parent interview would assess specific child behavior problems that have been identified as leading to substance use, rather than general child behaviors. For examples of appropriate measures, practitioners can refer to the National Institute on Drug Abuse publications Diagnostic Source Book on Drug Abuse Research and Treatment (Rounsaville, Tims, Horton, & Sowder, 1993) and Assessing Drug Abuse Among Adolescents and Adults: Standardized Instruments (Friedman & Granick, 1994).

### Involve Participants, Staff, and Other Stakeholders in the Evaluation Process

The evaluation design and process should include opportunities for input from a variety of project stakeholders, including staff, family participants, and community collaborators. The perspectives of these individuals on what can be gained from the intervention should be considered in framing the evaluation. One evaluator calls this the "development-in-context evaluation," in which stakeholders (including participants) design and implement an evaluation specific to the community in which the evaluation is taking place and inclusive of as many different community viewpoints as possible (Lerner, 1995).

Although it may be fairly easy to obtain evaluation input from professionals (e.g., staff and community collaborators), in many cases family participants are reluctant to be part of a research effort. Researchers have documented that family members often decline to participate in a project when it involves evaluation, in part because they are not informed about evaluation methods and purposes. This may result in selective participation (i.e., only those individuals who want to change participate) or a low recruitment or retention rate. Each of these problems can threaten the validity of the project findings (Spoth & Molgaard, 1993; Spoth & Redmond, 1994). Some studies, however, have demonstrated that involving participants in the collection of data about participation decisions can be helpful to the success of the project design.

To overcome these problems, it is important to determine the reasons for a family's reluctance to participate in research and to offer them opportunities to help design it. Program developers can achieve this by working with the project evaluator to hold focus groups with potential participants, during which various types of research methodologies could be presented. The potential participants could provide feedback regarding the feasibility of these methods and the barriers these methods might present to participation.

### Consider Cost Factors

Selection and design of an evaluation always involve tradeoffs among costs, results gained from incurring those costs, and outcomes lost by not incurring them. As a rule of thumb, the more rigorous the evaluation, the more it will cost. The amount of evaluation rigor required to demonstrate success varies, however, depending in part on how an intervention is tailored (through the assessment and planning process) to a local site. Practitioners should consider the following tradeoffs between costs and desired outcomes when choosing an evaluation design.

#### Documentation of Significant Improvements in Outcome

The level of risk factors, needs of the families who are the target of an intervention, and the number of families receiving intervention must be sufficient to allow demonstration of a clear improvement in specified outcomes. Otherwise, it will be difficult for practitioners to demonstrate a change that justifies the costs of the intervention.

#### Recruitment and Participation

As discussed earlier in this chapter, practitioners may need to conduct surveys or focus groups with the target population to determine population barriers and needs. These activities can be costly, but without adequate recruitment and participation, project implementation may be futile.

#### Use of Process Data During or After Evaluation

As part of the evaluation design process, the project team must decide how process evaluation data will be used during project implementation. These data - for example, information on participation rates - could be examined periodically during project implementation so changes can be made in intervention delivery to improve participation rates. Alternatively, the data could be examined only after intervention delivery has been completed. As suggested earlier, each of these options has associated costs and benefits that should be carefully considered.

#### Purpose of the Evaluation

The purpose and cost of an evaluation design will vary depending on whether the evaluation is intended to gain funding for the program (which could require a rigorous evaluation of considerable scope and cost) or to assess aspects of intervention implementation (which could allow an evaluation of more limited scope and cost).

#### Length of the Evaluation

Before choosing an evaluation design, the project team must decide how long participants will be assessed after the intervention has ended, as well as the costs associated with this decision. For example, the potential outcomes of a family skills training intervention that targets families of children diagnosed with conduct disorder could address changes in family risk and protective factors immediately after the intervention and at 1-year intervals for a designated period afterward or continue the evaluation to determine whether these children engage in substance abuse when they are adolescents. If a long-term evaluation strategy is chosen, practitioners should remember to adopt an appropriate sampling design to be able to make valid inferences after accounting for attrition and other confounding effects.

## Conclusion

Many practitioners face challenges in their efforts to intervene with families to prevent substance abuse by the children. Despite these difficulties, a growing body of research and practice literature has documented strategies to enhance the chances that prevention efforts will be successful. Key to this success is employing strategies that involve participants in planning and decisionmaking at each stage of development. In this way, the design and implementation of the intervention will be more likely to match their needs, strengths, and expectations. The information and strategies presented in this chapter offer substantial guidance to prevention planners in tailoring a successful intervention.

## References

Aktan, G. B., Kumpfer, K. L., & Turner, C. W. (1996).Substance Use and Misuse, 31
Barton, C., Alexander, J. F., Waldron, H., Turner, C. W., & Warburton, J. (1985).American Journal of Family Therapy, 13
Berry, M. (1992).Social Work, 37
Boyd-Franklin, N. (1990).Minorities and family therapy
Catalano, R. F., Haggerty, K. P., Gainey, R. R., Hoppe, M. J., & Social Development Research Group. (1995).Reducing parental risk factors for children's substance abuse: Preliminary outcomes with opiate-addicted parents.
Chalifour, I. (1993).Effective hiring practices: A look at personality, attitudes, and skills
Cochran, M., & Woolever, F. (1983).Changing families
The Creating Lasting Impressions program of the Council on Prevention and Education: Substances. Louisville, Kentucky.
Deutelbaum, W. (1992).The Prevention Report
Families and Schools Together (FAST), Family Service. Madison, Wisconsin.
Families in Focus, Cottage Program International. Salt Lake City, Utah.
Felner, R. D., Brand, S., Erwin Mulhall, K., Counter, B., Millman, J. B., & Fried, J. (1994).Journal of Primary Prevention, 15
Forehand, R., & Long, N. (1988).Advances in Behaviour Research and Therapy, 10
Friedman, A. S., & Granick, S. (Eds.). (1994).Assessing drug abuse among adolescents and adults: Standardized instruments
Gordon, D. A., Arbuthnot, J., Gustafson, K. E., & McGreen, P. (1988).American Journal of Family Therapy, 16
Guerney, L. F., & Wolfgang, G. (1981).Journal of Clinical Child Psychology, 10
Hawkins, J. D., Arthur, M. W., & Catalano, R. F. (1994).Preventing substance abuse.
Hawkins, J. D., Catalano, R. F., Jones, G., & Fine, D. (1987).Children to citizens: Families, schools, and delinquency prevention
Hawkins, J. D., Catalano, R. F., Morrison, D. M., O'Donnell, J., Abbott, R. D., & Day, L. E. (1992).Preventing antisocial behavior: Interventions from birth through adolescence
Head Start Bureau. (1994).Helping children affected by substance abuse: A manual for the Head Start management team.
Henggeler, S. W., Rodick, J. D., Borduin, C. M., Hanson, C. L., Watson, S. M., & Urey, J. R. (1986).Developmental Psychology, 22
Indian Health Service. (1995).Comprehensive health care program for American Indians and Alaska Natives.
Kansas Family Initiative, Kansas Department of Social and Rehabilitation Services. Topeka, Kansas.
Kosterman, R., Hawkins, J. D., Spoth, R., Haggerty, K. P., & Zhu, K. (1997).Journal of Community Psychology, 25
Kretzmann, J. P., & McKnight, J. L. (1993).Building communities from the inside out: A path toward finding and mobilizing a community's assets.
Kumpfer, K. L., & DeMarsh, J. P. (1987).Prevention services for children of substance-abusing parents.
Kumpfer, K. L., Molgaard, V., & Spoth, R. (1996).Preventing childhood disorders, substance abuse, and delinquency
Kumpfer, K. L., & Turner, C. W. (1990--91).International Journal of the Addictions, 25
Kumpfer, K. L., Turner, C. W., & Palmer, S. (1991)YCOSA Black Parenting Project: Third and fourth year evaluation report.
Lerner, R. M. (1995).America's youth in crisis: Challenges and ppportunities for programs and policies
Lochman, J. E., & Wells, K. C. (1996).Preventing childhood disorders, substance abuse, and delinquency
Loeber, R. (1988).Advances in clinical child psychology
Mann, B. J., Borduin, C. M., Henggeler, S. W., & Blaske, D. M. (1990).Journal of Consulting and Clinical Psychology, 58
McMahon, R. J., Forehand, R., & Griest, D. L. (1981).Journal of Consulting and Clinical Psychology, 49
McMahon, R. J., Slough, N. M., & Conduct Problems Prevention Research Group. (1996).Preventing childhood disorders, substance abuse, and delinquency.
McPherson, S. J., McDonald, L. F., & Ryer, C. W. (1983).Juvenile & Family Court Journal, 34
Millman, J. (1992).Parenting partnership manual
Myers, H. F., Alvy, K. T., Richardson, M., Arrington, A., Marigna, M., Huff, R., Main, M., & Newcomb, M. (1990).The Effective Black Parenting Program: A control research study with inner-city Black families.
Northwest Indian Child Welfare Association, Inc. (1993).Honoring the children.
Office for Substance Abuse Prevention. (1991).Parent training is prevention: Preventing alcohol and other drug problems among youth in the family
Parenting for Prevention, King County Department of Alcohol and Substance Abuse Services. Seattle, WA.
Prinz, R. J., & Miller, G. E. (1996).Preventing childhood disorders, substance abuse, and delinquency.
Rounsaville, B. J., Tims, F. M., Horton, A. M., & Sowder, B. J. (Eds.). (1993).Diagnostic source book on drug abuse research and treatment
Santisteban, D. A., Coatsworth, J. D., Perez-Vidal, A., Mitrani, V., Jean-Gilles, M., & Szapocznik, J. (1995).Brief structural/strategic family therapy with African-American and Hispanic high-risk youth.
Santisteban, D. A., Szapocznik, J., Perez-Vidal, A., Kurtines, W. M., Murray, E. J., & Laperriere, A. (1996).Journal of Family Psychology, 10
Spoth, R., Ball, A. B., Klose, A., & Redmond, C. (1996).Health Education Research, 11
Spoth, R., & Conroy, S. (1993).Journal of Rural Health, 9
Spoth, R., & Molgaard, V. (1993).. Evaluation and the Health Professions, 16
Spoth, C., & Redmond, C. (1993).American Journal of Health Promotion, 8
Spoth, C., & Redmond, C. (1994).Psychology and Health: An International Journal, 9
Spoth, R., & Redmond, C. (1995).Journal of Family Psychology, 9
Spoth, R., & Redmond C. (1996).Family Relations, 45
Spoth, R., Redmond, C, Yoo, S., & Dodge, K. (1993).Family Perspective, 27
Spoth, R., Redmond, C., Haggerty, K., & Ward, T. (1995).Journal of Marriage and the Family, 57
Spoth, R., Redmond, C., Hockaday, C., & Shin, C. (1996).Family Relations, 45
Spoth, R., Redmond, C., Hockaday, C., & Yoo, S. (1997).American Journal of Community Psychology, 24
Spoth, R., Redmond, C., Kahn, J., & Shin, C. (in press-a).Family Process.
Spoth, R., Redmond, C., Kahn, J., & Shin, C. (in press-b 1998).Journal of Consulting and Clinical Psychology.
Springer, J. F., Phillips, J. L., Phillips, L., Cannady, L. P., & Kerst-Harris, E. (1992).Journal of Community Psychology,
Szapocznik, J., Perez-Vidal, A., Brickman, A., Foote, F. H., Santisteban, D., Hervis, O. E., & Kurtines, W. M. (1988).Journal of Consulting and Clinical Psychology, 56
Szapocznik, J., Santistiban, D., Kurtines, W., Perez-Vidal, A., & Hervis, O. (1983).Hispanic Journal of Behavioral Sciences, 6
Szapocznik, J., Santisteban, D., Rio, A., Perez-Vidal, A., Santisteban, D., & Kurtines, W. M. (1989).Hispanic Journal of Behavioral Sciences, 11
Weiss, H. B. (1995).Raising our future: Families, schools, and communities joining together - A handbook of family support and education programs for parents, educators, community leaders, and policy makers
Wolchik, S. A., West, S. G., Westover, S., Sandler, I. N., Martin, A., Lustig, J., Tein, J. Y., & Fisher, J. (1993).American Journal of Community Psychology, 21
Yoshikawa, H. (1994).Psychological Bulletin, 115