# Analysis of Evidence and Recommendations for Practice

Family-centered approaches to the prevention of substance abuse among children and adolescents are used in a variety of settings and have diverse goals. Three approaches were identified and included in this guideline because evidence of their effectiveness is documented in the literature: parent and family skills training, family in-home support, and family therapy. Family therapy and parent and family skills training are commonly provided in clinical settings and are often used to help families address child behavior problems. In-home family support is usually embedded in programs that focus on family preservation, child abuse, or other health care issues. This approach can be found in child welfare programs, health-based organizations, schools, neighborhood centers, and as part of church-related activities. Review and analysis of the research and practice evidence for each of these approaches follow.

This chapter describes an analysis of the effectiveness of family-centered approaches to substance abuse prevention and provides recommendations for practice.

This chapter includes the following four major sections:

1. Classification of Preventive Measures and Description of Approaches - The first part of this section presents a classification scheme for developing preventive measures and categorizing them according to the risk levels of their target audiences. The next part of this section defines the term prevention approach and the three family-centered approaches evaluated in this guideline.
2. Analysis of Evidence - This section describes the analyses of the research and practice evidence for each of the three prevention approaches. The presentation of each approach includes the following:
  a. The conceptual foundation for the approach.
  b. A list of the research and practice evidence reviewed.
  c. The level of evidence found, including the conclusions drawn from the evidence and the strength of the evidence supporting the conclusions (see the discussion of the levels of evidence in About This Guideline).
  d. Lessons learned for each prevention approach based on the research and practice evidence reviewed.
  e. Suggestions for future research based on the research and practice evidence reviewed.
  f. Recommendations for practice, observations, and interpretations made by the Expert Panel regarding the three prevention approaches (see the discussion of recommendations for practice in About This Guideline).
3. General Suggestions for Future Research - This section includes suggestions for future research that relate to more than one of the three prevention approaches.
4. General Recommendations for Practice - This section includes recommendations for practice that relate to more than one of the three prevention approaches.

An appendix to this chapter, Research and Practice Evidence Abstracts, describes in a standard format each of the research studies and practice cases that was analyzed. Each abstract describes the study design (where appropriate), the overall intent of the study or program, and the findings or results most relevant to the prevention approach in question.

## Classification of Preventive Measures and Description of Approaches

This section presents a classification scheme for developing preventive measures and categorizing them according to the risk levels of their target audiences. It is followed by a definition of the term prevention approach and descriptions of the three family-centered approaches evaluated in this guideline.

### Classification Scheme for Prevention

According to Gordon (1983), prevention efforts can be "operationally classified on the basis of the population groups among which they are optimally used." Gordon's classification scheme incorporates a cost-benefit assessment with regard to various populations. In the context of family-centered substance abuse prevention efforts, the benefits of working with families at various degrees of risk for substance abuse are weighed against the cost to society for carrying out specific interventions with these families. Gordon defined three categories of preventive measures: Universal, selective, and indicated (Gordon, 1983, 1987). The term preventive measure here denotes a cluster of interventions designed for a group of families sharing a common level of risk for substance abuse.

#### Universal Preventive Measures

Universal preventive measures are desirable for everyone. These measures "can be advocated confidently for the general public" (Gordon, 1983, p. 108). In relation to substance abuse, universal measures are directed to the general population or to a general subsection of the public (e.g., all families in a community, school district, or religious institution). These families have not been identified on the basis of risk factors related to substance abuse; however, exposure of these families to prevention strategies could reduce the possibility of future substance abuse. The underlying assumption of universal measures is that all children benefit when parents and families have good nurturing skills that can create protective family and community environments.

#### Selective Preventive Measures

Broadly, selective preventive measures are "advisable for population subgroups distinguished by age, sex, occupation, or other evident characteristics, but who are perfectly well" (Gordon, 1983, p. 108). In the field of substance abuse prevention, selective measures are directed to subgroups of families with children who do not yet abuse substances but who, as a subgroup, have an above average risk for developing substance abuse problems. Examples of these subgroups are people living in areas characterized by disorganization, violence, or drug trafficking; single-parent families or families of divorce; and families in economic distress (e.g., the unemployed, the homeless, recipients of Temporary Assistance for Needy Families (TANF), and the low-income working poor). The goal of selective measures is to ensure that families in these targeted subgroups have access to interventions designed to reduce family risk factors that are characteristic of the subgroup and could lead to adolescent substance abuse - and to strengthen protective factors that can help prevent adolescent substance abuse.

#### Indicated Preventive Measures

Gordon states that "indicated preventive measures should be applied only in the presence of a demonstrable condition that identifies the individual as at higher-than-average risk for the future development of a problem" (Gordon, 1983, p. 108). When applied to family-centered substance abuse prevention, these measures are directed to specific families (as opposed to subgroups) who have children with known, identified risk factors. As with other types of preventive measures, the children of these families are not yet known to be abusing substances. Examples of populations targeted for indicated preventive measures include families who have children with serious behavioral, conduct, emotional, or psychiatric disorders requiring clinical treatment; families who have children with delinquency problems; and families with substance-abusing parents, a history of physical or sexual abuse, evidence of neglect, extreme family conflict, or other types of violence. Families receiving indicated prevention interventions are usually identified through child welfare programs, mental health clinics, substance abuse treatment programs for adults, and schools and other community institutions that work with families whose children are having serious difficulties with behavior or personal adjustment.

### Prevention Approaches Analyzed in This Guideline

A prevention approach is defined as a group of prevention activities that broadly share common assumptions (theories or hypotheses), methods and strategies, and desired outcomes. The three prevention approaches evaluated in this chapter (parent and family skills training, family in-home support, and family therapy) are relevant to the outcome of preventing or reducing child and adolescent substance abuse. However, some interventions described in the approaches are not designed to directly prevent substance abuse. Rather, they are intended to decrease risk factors (or their effects) and increase protective factors (or their effects) that are related to adolescent substance abuse. Changing behaviors and conditions through these interventions should result in a decrease in the likelihood of substance abuse.

During the evaluation phase of guideline development, research and practice evidence was identified and grouped within the three prevention approaches. As appropriate, the prevention approaches were then classified or subgrouped according to the prevention classification scheme of Gordon (1983, 1987). Brief descriptions of the prevention approaches are provided in the following sections.

#### Prevention Approach 1: Parent and Family Skills Training

Parent and family skills training is designed to improve family communication skills, teach parents skills for nurturing and protecting their children, modify counterproductive parenting behavior, decrease children's antisocial and other problem behaviors, and encourage the development of prosocial skills. This prevention approach is divided into two subgroups: (1) parent and family skills training as universal and/or selective preventive measures and (2) parent and family skills training as indicated preventive measures.

#### Prevention Approach 2: Family In-Home Support

Family in-home support provides parents and families with services tailored to their unique needs with the goal of stabilizing the family environment so that parents are better able to protect and nurture their children. In this guideline, family in-home support is characterized as an indicated preventive measure.

#### Prevention Approach 3: Family Therapy

Family therapy helps family members reduce maladaptive family functioning, decreases negative behavior, and fosters skills for healthy family interactions. In this guideline, family therapy is characterized as an indicated preventive measure.

## Analysis of Evidence

This section presents the results of the Expert Panel's analysis of the research and practice evidence for each of the three prevention approaches. The approaches are reviewed and presented in a standardized format that allows the reader to systematically examine their purposes, similarities, and differences. Within each prevention approach presented, several elements of the research and practice evidence are discussed. These elements are the following:

- Conceptual Framework of the Approach or Cluster.
- Overview of the Evidence Reviewed.
- Levels of Evidence.
- Lessons Learned.
- Suggestions for Future Research.
- Recommendations for Practice.

## Prevention Approach 1: Parent and Family Skills Training

Family functioning, structure, and values have a significant impact on children's capacity to develop prosocial skills and cope with life's challenges. Parent and family skills training interventions can have a positive effect on parental and familial roles and interactions by providing family members with new skills that promote better nurturing and protection of children. This type of training can be used to decrease antisocial, aggressive, or other problem behaviors of children and parents; help children develop prosocial skills; and foster specific parenting skills. It can also be used to train parents to deal with children who are particularly challenging or have behavior problems. Parent and family skills training interventions can be delivered as indicated, selective, or universal preventive measures.

In the following discussion of the effectiveness of parent and family skills training, the three-part classification scheme for prevention described earlier was used to divide the evidence into two intervention clusters: universal and/or selective preventive measures, and indicated preventive measures. The universal and selective classifications were combined because there was insufficient research literature to permit separate evaluations of the evidence and because these classifications have more similarities than differences.

### Conceptual Framework for Cluster 1: Parent and Family Skills Training as Universal and/or Selective Preventive Measures

The concept underlying parent and family skills training as universal and/or selective preventive measures is that promotion of prosocial behaviors and skills should prevent the development of risk factors for substance abuse, such as antisocial and other problem behaviors, and help children to develop and strengthen the factors that protect against substance abuse.

The parent and family skills training interventions described in this cluster are targeted toward families in the general population whose children have not been selected on the basis of risk or symptoms of problem behavior or toward families whose children are exposed to several risk factors and therefore at higher than average risk for developing substance abuse problems. These parent and family skills training interventions are usually implemented in voluntary, nonclinical settings.

Parent and Family Skills Training Clusters

The discussions for each cluster include overviews of the research and practice evidence and levels of evidence. Lessons learned and suggestions for future research are then presented for the entire approach.

Presentation of the prevention approach concludes with recommendations for practice for both clusters.

In this cluster, family skills training interventions involve parents or parents and children in structured curriculum activities designed to identify opportunities for change and improve family functioning, including strengthening children's prosocial behaviors and skills. Also in this cluster, some interventions focus specifically on strengthening parents' skills by identifying opportunities for improved parenting, helping parents learn to deal with particularly challenging children, and teaching parents how to strengthen their children's prosocial behaviors and skills.

### Overview of the Evidence for Approach 1, Cluster 1: Parent and Family Skills Training as Universal and/or Selective Preventive Measures

Analysis of the effectiveness of parent and family skills training as universal and/or selective preventive measures is based on 14 research studies and 6 practice cases. The objectives of the interventions reviewed in this cluster focused on such changes as acquiring skills and increasing knowledge for parents and improving behavior for children. The expected changes for parents included acquiring or improving parenting skills, child management abilities, and psychological helping skills; developing relationships; and developing empathy. Expected changes for families included conflict resolution and improvements in family cohesion, organization, and relationships.

For youth, expected changes included improvements in general child behavior, psychological adjustment, attachment to family, and commitment to school.

Activities in these interventions included parent and child skills training sessions (primarily in the form of didactic and group sessions), as well as therapy and video-based sessions. Specifically, these included videotape- and curriculum-based training and modeling sessions; didactic, role-playing, and skill practice sessions; and cognitive-behavioral workshops and training sessions.

The following studies examined interventions that included parent training without child involvement:

1. Felner et al. (1994) evaluated the effectiveness of a work-site-based parenting program designed to improve parent-child interactions by increasing the knowledge and improving the attitudes and discipline skills of parents.
2. Myers et al. (1990) examined a culturally appropriate cognitive-behavioral parenting skills-building program.
3. Guerney (1977) evaluated the effectiveness of a skills training program designed to improve psychological helping skills for foster parents.
4. Guerney and Wolfgang (1981) evaluated a skills training program for foster parents that focused on the development of skills for child management, empathy, relationship development, and understanding of children's needs and development.
5. Thompson, Grow, Ruma, Daly, and Burke (1993) evaluated the effectiveness of a parenting program designed to teach middle and lower income parents child management skills to decrease their children's developmental, learning, and behavioral problems.
6. Knapp and Deluty (1989) compared the effectiveness of a behavioral parent training program involving modeling and role playing with a parent training program involving readings, brief review testing, and discussions.
7. Wolchik et al. (1993) evaluated the effectiveness of a parent-based intervention designed to improve psychological adjustment in children of divorced mothers.

The following studies examined interventions that involved parent training plus family skills training:

1. Catalano, Haggerty, Gainey, Hoppe, and the Social Development Research Group (1995) compared the effectiveness of methadone maintenance treatment alone and treatment by a methadone maintenance program that included a parent training component designed to increase relapse prevention skills, improve parenting skills and child skills and behavior, and reduce parent and child drug use.
2. Spoth, Redmond, Haggerty, and Ward (1995) and Kosterman, Hawkins, Haggerty, Spoth, and Redmond (1996, 1997) assessed the efficacy of a theory-based family skills training intervention designed to prevent adolescent substance abuse and other problem behaviors.
3. Spoth and Redmond (1996), Spoth, Yoo, Kahn, and Redmond (1996), and Spoth, Redmond, Hockaday, and Yoo (1997) examined models of theory-based mechanisms of change in selected outcomes, incorporating intervention parameters such as session attendance levels.
4. Spoth (in press), Spoth, Redmond, and Shin (in press), Spoth, Redmond, Shin, and Huck (in press), and Spoth, Reyes, and Redmond (1997) evaluated the effectiveness of a family competency training program designed to enhance protective parent-child interactions and to reduce children's risk for early substance use initiation.

The following three studies examined interventions that included parent training with separate child training plus family skills training:

1. Kumpfer and DeMarsh (1987) compared the effectiveness of three parent-child-focused, family-based prevention conditions for reducing the substance abuse risk status of children living with a substance-abusing parent (parent training alone, parent training plus children's skills training, and parent and child skills training plus a family skills training program).
2. Kumpfer, Turner, and Palmer (1991) evaluated the effectiveness of a behaviorally oriented parent-child-focused family skills training program for reducing the substance abuse risk status of children in African-American families in rural Alabama living with a substance-abusing parent. The family skills training program was comprised of behavioral parent training sessions, separate children's training sessions, and joint parent and child training sessions.
3. Aktan, Kumpfer, and Turner (1996) evaluated the effectiveness of a family skills training program for inner-city African-American families that is intended to reduce risk factors for substance use in families in which one parent is known to abuse substances. The program consists of concomitant parent training and children's skills training, followed by family skills training classes.

The following three case studies involve parent training without child involvement:

1. The Kansas Family Initiative is a statewide prevention effort designed to train parents about substance abuse risk factors, developing a family position on alcohol and illicit drugs, techniques for alcohol and other drug refusal, managing family conflicts, and strengthening family bonds.
2. The Parenting for Prevention program is a multiagency parenting education and training program designed to reduce risks associated with compromising the health and protection of children, assist parents with child-rearing challenges through effective parenting, and promote bonding within families and with the community.
3. The Communication and Parenting Skills program was a nine-session skills-oriented course designed to teach parental modeling of positive attitudes and behaviors and teach effective communication (Klein & Swisher, 1983). The program included class discussions, assigned reading, skills training, modeling of desired responses, homework, reinforcement, and values clarification. The following case study involved parent training with separate child training: The Creating Lasting Impressions program involved the engagement of church communities in rural, suburban, and urban settings. It involved training in substance abuse issues, family management and enhancement, communication skills for parents and youth, and substance abuse issues for youth.

The following two practice cases involve family skills training:

1. The Families in Focus program involves in-home activities designed to build family cohesion, adaptability, and communication as a way to prevent substance abuse.
2. The Families and Schools Together program is a family- and school-based prevention program that emphasizes enhancement of family functioning and development of protective factors, prevention of school failure and substance abuse, and reduction in family stress. Activities focus on cooperation and collaboration, including assembling family flags, learning songs, and hosting meals.

Abstracts of the research and practice cases used in this analysis are provided at the end of this chapter. Assessment of the level of evidence for Approach 1, Cluster 1 is summarized on page 3-12.

### Conceptual Framework for Approach 1, Cluster 2: Parent and Family Skills Training as Indicated Preventive Measures

The concept underlying parent and family skills training as indicated preventive measures is that decreasing children's and family's antisocial and other problem behaviors, fostering prosocial skills in children, and improving the family environment should reduce children's risk factors for developing substance abuse problems and enhance protective mechanisms relative to substance abuse.

This cluster describes family skills training and parent training interventions for families with children who are exposed to multiple risk factors or who have a high level of exposure to a single risk factor. The children have behavior disorders or conduct problems and are therefore at high risk for, but are not yet experiencing, substance abuse problems. These interventions are generally carried out in therapeutic or clinical settings and often include structured skills development, therapeutic counseling, and discussion groups.

Level of Evidence for Approach 1, Cluster 1: Parent and Family Skills Training as Universal and/or Selective Preventive Measures

The research and practice evidence in this cluster relates to parent and family skills training as universal and/or selective preventive measures - interventions for parents and families with children who have not yet developed diagnosed problem behaviors or engaged in substance abuse, but who belong to a subgroup whose risk of experiencing substance abuse is higher than average or interventions for families with children who have not been selected on the basis of any sign of substance abuse or elevated level of risk.

The research and practice evidence reviewed indicates that it is possible to successfully implement parent and family skills training as universal and/or selective preventive measures as follows:

- There is strong evidence that these interventions can stabilize or improve conditions that allow development of risk factors, such as poor parent-child communication, child problem behavior, inadequate parenting skills, poor family relationships, parental substance use, and deficient family functioning (family conflict, poor family communication, and family disorganization).
- There is suggestive but insufficient evidence that, when specifically targeted, these interventions can improve children's social skills and prosocial behavior.
- There is suggestive but insufficient evidence that, when specifically targeted, these interventions can reduce parental stress and depression, improve children's self-esteem, and promote improvements in acculturation differences between parents and children.
- There is suggestive but insufficient evidence that a combination of parent training, children's social skills training, and family relationship enhancement training leads to greater overall improvements in parent-child relationships than does any of these interventions alone.
- There is suggestive but insufficient evidence that these interventions can delay the onset and progression of substance use among young adolescents.

In this cluster, interventions focus on developing family skills to address dysfunctional and counterproductive family functioning and behavior, as well as on reducing or eliminating children's problem behaviors. These interventions always involve parents and children in structured curriculum activities designed to improve family functioning. Although parents are always participants in these interventions, the involvement of children ranges from moderate to extensive. Parent training interventions in this cluster focus on development of parenting skills to address dysfunctional and counterproductive parenting practices, to deal with particularly challenging children, and to reduce or eliminate children's problem behaviors.

### Overview of the Evidence for Approach 1, Cluster 2: Parent and Family Skills Training as Indicated Preventive Measures

In the research studies and practice cases reviewed for this cluster, the objectives of the interventions were such changes as acquiring skills and increasing knowledge for parents, changing parents' attitudes toward their children, and improving behavior for children. The expected changes for parents included acquiring or improving parenting skills, child management abilities, problem-solving skills, communication skills, and crisis management abilities. The expected changes for youth included improving general behavior, acquiring or improving self-control and compliance, reducing antisocial and other problem behaviors, and reducing arrest rates among offenders.

Activities used to meet the intervention's objectives were typically parent and child skills training sessions, primarily didactic and group sessions, as well as therapy and video-based sessions. Specific activities included videotape- and manual-based training and modeling sessions; didactic, role-playing, and skills practice sessions; and cognitive-behavioral training sessions.

The following studies examined interventions that involved parent training without child involvement:

1. Arnold, Levine, and Patterson (1975) examined the effectiveness of a parent training program involving social learning techniques of child management to reduce the rates of deviant behavior for targeted children's siblings.
2. Dubey, O'Leary, and Kaufman (1983) compared the effectiveness of behavior modification and a communications-based parent training program to reduce child hyperactivity, problem severity, and daily problem occurrence in the parents' hyperactive children.
3. Anastopoulos, Shelton, DuPaul, and Guevremont (1993) evaluated changes in parent functioning resulting from parental participation in a behavioral parent training program designed for school-aged children with attention deficit hyperactivity disorder.
4. Patterson (1974, 1975) examined the effectiveness of a social-learning-based child management program designed to alter the behavior of aggressive children.
5. Webster-Stratton (1984) evaluated the effectiveness of providing mothers with child management skills to enhance their parenting and reduce noncompliance by their children with oppositional behaviors. This study compared individual therapy with therapist-led therapy based on a standardized videotaped modeling program.
6. Webster-Stratton (1990a) evaluated the effectiveness of a self-help videotaped parent training program with and without therapist consultation. The program was designed to provide parents with skills to reduce the noncompliance of their children with conduct disorder, to enhance maternal parenting skills, and to improve parent-child communication.
7. Webster-Stratton, Kolpacoff, and Hollinsworth (1988, 1989) and Webster-Stratton (1990b) evaluated the effectiveness of three parent training treatment methods to reduce conduct disorders and to improve parents' behaviors and perceptions. The treatments consisted of individually administered, videotaped modeling sessions; therapist-led group discussion and videotaped modeling; or therapist-led group discussion.
8. Webster-Stratton (1994) evaluated the effectiveness of a basic parenting skills training program of videotaped and group discussion designed to model parenting skills as compared with a program that added a broader-based, videotape and group discussion component designed to train parents to cope with interpersonal distress through improved communication, problem solving, and self-control skills.

The following research focused on parent training with separate child training:

1. Horn et al. (1991) and Ialongo et al. (1993) evaluated the effectiveness of high- or low-dose methylphenidate treatment either alone or in combination with a behavioral parent training and child cognitive-behavioral self-control instruction program for families with children having attention deficit hyperactivity disorder.
2. Tremblay et al. (1991) and Tremblay, Pagani-Kurtz, Masse, Vitaro, and Pihl (1995) evaluated the effectiveness of parent and child training on the reduction of antisocial behavior among disruptive boys.
3. Dishion and Andrews (1995) evaluated a program designed to provide a supportive, nonstigmatizing intervention for high-risk families to promote adaptation in the adolescent years by reducing maladaptive processes. The parent-focused curriculum targeted parent family management practices and communication skills. The teen-focused intervention targeted self-regulation and prosocial behavior within the context of parent and peer environments.

Numerous studies examined family skills training interventions.

1. Bank, Marlowe, Reid, Patterson, and Weinrott (1991) compared the effectiveness of a parent training intervention with services traditionally provided by the juvenile court and the community.
2. Baum and Forehand (1981) examined the long-term maintenance effect of a parent training program on mother-child interactions, parents' perceptions of child adjustment, and parent satisfaction.
3. Forehand and Long (1988) and Long, Forehand, Wierson, and Morgon (1994) conducted two follow-up evaluations of subjects who had participated in a series of parent training programs several years earlier (McMahon & Forehand, 1984). Parents had been taught to recognize and reward appropriate behavior, ignore minor inappropriate behavior, issue commands and reinforce compliance, and use the discipline technique of "time-out" for noncompliance.
4. McMahon, Forehand, and Griest (1981) examined the efficacy of incorporating formal training in social learning principles into a behavioral parent training program for mothers of children referred for the treatment of noncompliance and other oppositional behaviors.
5. Rogers, Forehand, Griest, Wells, and McMahon (1981) examined whether parents of low, middle, and upper socioeconomic status differed in their interactions with and perceptions of their children and in their responsiveness to parent training.
6. Fleischman (1981) evaluated the effectiveness of parent-mediated treatment of boys with conduct problems on changes in child aversive behavior and parental perceptions of child behavior.
7. Kazdin, Siegel, and Bass (1992) assessed the effects of parent management training and cognitive-behavioral problem-solving skills training on children referred to a psychiatric facility for severe antisocial behavior.
8. Szapocznik et al. (1986) compared the effectiveness of bicultural effectiveness training and structural family therapy in improving measures of family interactional patterns, family levels of acculturation and biculturalism, and adolescent behavior problems and psychopathology.
9. Szapocznik, Rio, et al. (1989) compared the effectiveness of a minimum-contact control condition with family effectiveness training that targets maladaptive family interactions and intergenerational and intercultural conflicts.
10. Santisteban et al. (1996) examined the effectiveness of engagement family therapy, which combines brief strategic family therapy with strategic structural systems engagement as a method to bring into and engage in treatment those families described as "difficult to reach."

The following four studies examined interventions that consisted of parent training plus family skills training:

1. Bernal, Klinnert, and Schultz (1980) compared the effectiveness of behavioral parent training and client-centered parent counseling in reducing problem behaviors among children with conduct disorder.
2. Dumas (1984) evaluated the effectiveness of a behavioral parent training program designed to teach parents to respond appropriately to and modify the aggressive and oppositional behavior of their children.
3. Hughes and Wilson (1988) compared the effectiveness of contingency management training and communication skills training to modify the behavior of children with conduct disorder.
4. Wahler, Cantor, Fleischman, and Lambert (1993) compared the impact of parent training alone and in combination with "synthesis teaching," a process in which the therapist and parent discuss the parent's child care experiences and other experiences that influence parenting.

The following practice evidence for parent and family skills training as indicated preventive measures focused on family skills training:

The Nurturing Program for Parents and Children was designed to modify abusive or potentially abusive parent-child interactions by providing training on developmental expectations, empathy, behavior management, and self-awareness.

Abstracts of the research and practice cases used in this analysis are provided at the end of the chapter.

Although the effectiveness of the two clusters that comprise this approach are evaluated individually, lessons learned and suggestions for future research are presented collectively below.

### Lessons Learned From Evidence Reviewed for Prevention Approach 1: Parent and Family Skills Training (Clusters 1 and 2)

The research and practice evidence reviewed in this prevention approach provides for several lessons learned, as follows:

1. Research demonstrates that parent and family skills training has positive effects on measures related to parents, the family, and children. When the research is taken as a whole, positive outcomes include increases in parenting skills, problem-solving skills, child management skills, and coping skills; and improvements in attitudes, including acceptance of children (Aktan et al., 1996; Catalano et al., 1995; Felner et al., 1994; Forehand & Long, 1988; Guerney, 1977; Guerney & Wolfgang, 1981; Kosterman et al., 1996, Kosterman et al., 1997; Kumpfer & DeMarsh, 1987; McMahon et al., 1981; Myers et al., 1990; Rogers et al., 1981; Spoth et al., 1995; Spoth & Redmond, 1996; Spoth, Redmond, & Shin, in press; Szapocznik, Rio, et al., 1986; Szapocznik, Santisteban, et al., 1989; Thompson et al., 1993; Webster-Stratton, 1990a; Wolchik et al., 1993).
2. Many studies have shown that parent and family skills training can improve parent-child family relations, increase family cohesion, and decrease family problem behaviors, family conflict, and substance abuse (Aktan et al., 1996; Anastopoulos et al., 1993; Dishion & Andrews, 1995; Dubey et al., 1983; Forehand & Long, 1988; Kumpfer et al., 1991; Kumpfer & DeMarsh, 1987; Long et al., 1994; Myers et al., 1990; Rogers et al., 1981; Szapocznik et al., 1989a; Webster-Stratton, 1984, 1994; Wolchik et al., 1993).
3. Positive outcomes for children include increases in prosocial behaviors and decreases in adverse behaviors such as hyperactivity, social withdrawal, aggression, and delinquency (Aktan et al., 1996; Anastopoulos et al., 1993; Arnold et al., 1975; Bank et al., 1991; Baum & Forehand, 1981; Dishion & Andrews, 1995; Dubey et al., 1983; Felner et al., 1994; Fleischman, 1981; Forehand & Long, 1988; Kazdin et al., 1992; Knapp & Deluty, 1989; Kumpfer & DeMarsh, 1987; Kumpfer et al., 1991; Long et al., 1994; McMahon et al., 1981; Myers et al., 1990; Patterson, 1974, 1975; Szapocznik, Rio, et al., 1986; Thompson et al., 1993; Webster-Stratton, 1984, 1990a, 1990b, 1994; Webster-Stratton et al., 1988, 1989).
4. Research on family skills training is suggestive of a relationship between increases in parental effectiveness and decreases in parental substance use (Aktan et al., 1996; Catalano et al., 1995). However, the nature of this relationship is unknown. Some positive effects may be due to children's exerting pressure on parents to stop substance use, a higher parental awareness of the effects of their drug use on family dynamics, and improvement in parents' communication skills.
5. Research yields suggestive findings that among parents being treated for substance abuse problems, family skills training may have an impact on substance use above and beyond the treatment program effect (Aktan et al., 1996; Catalano et al., 1995). Enhancing addiction treatment by adding parenting or family skills training may reduce the likelihood of relapse. This may be particularly true for women because of an enhanced ability to communicate and manage the family efficiently following family skills training.
6. There are research findings indicating that videotaped training and education components can be effective and cost-efficient elements of parent training interventions that include therapist consultation and group discussion and can promote parental modeling and improve parenting skills (Webster-Stratton, 1984, 1990a, 1990b, 1994; Webster-Stratton et al., 1988, 1989).

Level of Evidence for Approach 1, Cluster 2: Parent and Family Skills Training as Indicated Preventive Measures

The research evidence in this cluster focuses on parent and family skills training as indicated preventive measures - interventions involving parents and children in structured activities designed to improve family functioning and parenting skills, delivered to families in which there are children (and possibly parents) with identified, diagnosed problem behaviors and who are at high risk for substance abuse problems.

The research and practice evidence reviewed indicates that it is possible to successfully implement parent and family skills training as indicated preventive measures, as follows:

- There is strong evidence that these interventions can improve adverse child and parenting behaviors that are specifically targeted for improvement, including child problem behavior, parenting skills, and family functioning issues, such as family organization, communication, bonding, and conflict.
- There is strong evidence that these interventions have positive and lasting effectiveness in improving parenting skills and behaviors and reducing diagnosed problem behaviors in children.
- There is suggestive but insufficient evidence that, when specifically targeted, these interventions can reduce parents' stress, depression, and alcohol and substance use; improve children's self-esteem; and promote improvements related to differences in acculturation between parents and children.

### Suggestions for Future Research for Prevention Approach 1: Parent and Family Skills Training (Clusters 1 and 2)

The research and practice evidence reviewed in this prevention approach provides for several suggestions for future research.

1. Research and practice evidence suggests that parent and family skills training reduces social isolation among parents and families (Kumpfer & DeMarsh, 1987; Families and Schools Together). However, research is needed on the long-term impact of improvements in the social health of families and the reduction of social isolation as it relates to the prevention of substance abuse.
2. Future research on parent and family skills training should include ways to improve the effectiveness of substance abuse prevention programs for specific populations by making them culturally appropriate and regionally and developmentally relevant (Guerney, 1977; Kumpfer et al., 1991; Kumpfer & DeMarsh, 1987; Myers et al., 1990). First, research is needed to identify the specific needs of special populations. Second, research is needed to identify interventions that best meet these needs. Third, research is needed to investigate optimal ways to deliver these interventions to special populations. Finally, research is needed to compare the effectiveness of culturally tailored parenting programs with that of generic training programs presented to specific and special populations.
3. There is a need for further research on parent and family skills training to examine issues such as recruitment and retention, expected outcomes, and content and delivery styles for different types of training (Bernal et al., 1980; Dishion & Andrews, 1995; Fleischman, 1981; Guerney & Wolfgang, 1981; Horn et al., 1991; Kumpfer & DeMarsh, 1987; Myers et al., 1990; Santisteban et al., 1996; Spoth et al., 1995; Spoth & Redmond, 1996; Szapocznik, Santisteban, et al., 1989; Webster-Stratton, 1990a; Wolchik et al., 1993).
4. Although many parent and family skills training studies demonstrate short-term positive outcomes, some of which are maintained over time, a few demonstrate positive effects at long-term follow-ups that were not evident after treatment or at a short-term follow-up (Patterson, 1974, 1975; Webster-Stratton et al., 1988, 1989; Webster-Stratton, 1990b). Therefore, research should examine the long-term effects of family skills training, including effects not obvious during short-term follow-up. In particular, research should examine the effects of family skills training on substance abuse, delinquent behaviors, and academic performance in children through the late adolescent years and beyond. It is important to measure parent as well as child outcomes.
5. Although the development of communication skills is an effective prevention effort, evidence suggests that contingency management training is more effective (Hughes & Wilson, 1988). More research should compare the effectiveness of communication skills training and that of contingency management interventions for specific developmental periods.
6. Research should be undertaken to examine whether communication skills training is especially valuable at specific developmental periods in the life of the child, such as during late adolescence (Dishion & Andrews, 1995; Dubey et al., 1983; Hughes & Wilson, 1988; Klein & Swisher, 1983; Webster-Stratton, 1990a).
7. Future research on parent and family skills training should be conducted in partnership with parents and other stakeholders in the community the training is intended to benefit.

The following section consists of recommendations, observations, and interpretations made by Expert Panel members concerning the Parent and Family Skills Training approach. The basis for these recommendations includes the research and practice evidence reviewed in the Analysis of Evidence section, research and practice evidence not reviewed in this chapter, and the Prevention Enhancement Protocols System (PEPS) Expert Panel members' expertise, experiences, and opinions.

### Recommendations for Prevention Approach 1: Parent and Family Skills Training (Clusters 1 and 2)

The Expert Panel's recommendations regarding parent and family skills training focuses on topics such as cultural content, environmental context, multicomponent programs, and program retention, as follows:

1. The concept underlying this prevention approach has great potential and is expressed in various models of parent and family skills training interventions. Some models combine parent training and children's skills training with family therapy. Such comprehensive family skills training programs can address a broad array of family risk and protective factors for substance abuse. These programs can target the total family system, thereby preventing "family sabotage effects" that can emerge when only the individual child or parent is treated. Family skills training and parent training programs can be implemented more easily than family therapy because they require less skilled staff and are highly structured. Further, these programs can be modified and adapted with regard to ethnic and cultural appropriateness, regional applicability, and developmental relevance.
2. During planning and implementation of parent and family skills training programs, relevant cultural content should be incorporated into the program that will initiate positive changes in family dynamics and roles. Szapocznik and colleagues found that maximizing families' cultural strengths promotes better interactions within the family. Their research suggested that families who are not bicultural (i.e., effective in integrating traditional cultural norms with the norms of American society) may experience behavioral problems that place youth at risk for adolescent substance abuse. On the basis of this research, Szapocznik, Santisteban, Kurtines, Perez-Vidal, & Hervis (1984) and Szapocznik and Kurtines (1993) developed an intervention known as "bicultural effectiveness training" (BET), in which program content promotes family interactional processes that enhance biculturalism. BET was tested in a randomized study and found to be as effective as traditional family therapy (Szapocznik et al., 1996; Szapocznik, Murray, et al., 1986; Szapocznik, Santisteban, Rio, Perez-Vidal, & Kurtines, 1986).
3. In evaluating research on parents who are not successful in parent or family skills training, it is important to consider factors other than the failure of a parent training class to teach new skills. Rather, research suggests that a lack of success in parenting training may relate to serious problems in the parents' social lives and environmental context. These include problems such as violence in the family, unsafe neighborhoods, and poverty-related stresses that impede full engagement and participation in training. Other factors include poor parental communication and the class not being tailored to the parents' specific needs, including culture and language.
4. Research on parent and family skills training suggests that multifocus prevention efforts are superior to single-focus interventions. For example, superior outcomes are associated with parent training interventions that address multiple family and community contexts. Reducing social isolation, building peer support networks, increasing awareness of community resources, and teaching how to cope with depression and parenting stress exemplify some of the tasks a multifocus prevention effort might address.
5. Research demonstrates that parents of children with conduct problems, even those with multiple problems, are often successfully retained in parent training at high rates. This is in contrast to an opinion frequently expressed by prevention specialists that it is nearly impossible. It may be that parent training promotes parental retention because it is viewed by parents as a helpful and acceptable form of intervention and may increase parental hope and a sense of competence.
6. Parent training interventions are more effective for those with younger children than for those with older children with conduct problems. Prevention approaches should incorporate the concept that early intervention is superior to later intervention.
7. Prevention efforts that focus on parenting skills should include information about community resources that provide support to the family, especially those that help meet the biopsychosocial, cultural, and spiritual needs of families. For this reason, it is recommended that prevention practitioners and service providers develop strong mutual networks and become thoroughly acquainted with all available and relevant community resources.
8. Experience and research suggest that conducting interventions in the home is associated with certain advantages, such as the ability to involve all family members and to gain an understanding of a family's dynamics over time (Baum & Forehand, 1981; Catalano et al., 1995; McMahon et al., 1981; Patterson, 1974, 1975). Home-based interventions heighten the capacity to engage the entire family in the intervention and can offer improved opportunities to promote trust between the service provider and the client.

## Prevention Approach 2: Family In-Home Support as Indicated Preventive Measures

This approach attempts to prevent substance abuse among children and adolescents aby providing comprehensive, intensive, multipurpose services in the home and addressing a range of family problems, typically involving all family members.

### Conceptual Framework for Approach 2: Family In-Home Support as Indicated Preventive Measures

Families with multiple risk factors or a high level of risk for a single factor have numerous interrelated problems and needs that may benefit from being addressed concurrently. Many of these problems and needs have contexts both within and outside of the family. As indicated preventive measures, family in-home support provides parents and/or families with services that are tailored to their specific needs and that are intended to help stabilize the family environment so that parents are better able to nurture and protect their children. These intensive and comprehensive services are provided for several months to a year; are generally intended to serve multiple purposes; and address a range of family risk factors and immediate needs, such as transportation, food, clothing, advocacy, crisis intervention, counseling, and referral. They typically provide assistance to help keep the family intact. Services are received in the home, and family members are linked to other services outside the home. Among the most common goals of family in-home support are decreasing the likelihood of domestic violence, child abuse or neglect, or placement of children in foster homes or in institutions for juvenile delinquency.

### Overview of the Evidence for Approach 2: Family In-Home Support as Indicated Preventive Measures

Family preservation was the primary objective of the interventions reviewed in this prevention approach. These interventions encompassed changes such as the acquisition of skills for parents, decreases in child problem behaviors, and family reunification. Expected changes for parents included acquiring or improving parenting skills related to discipline, family relations, communication, and anger management, and decreasing the likelihood of parents engaging in child abuse and neglect. For youths, expected changes included diminishing rates of arrests and criminal activities among juvenile offenders. Expected changes for the entire family included preventing children from being removed from the family and, in other cases, reuniting previously removed children with their family.

Activities employed in these interventions included provision of direct services and social services. Direct services included transportation, cash assistance, clothing, food, and help with home repairs. Social services included individual and family counseling, crisis intervention, behavior management training, reunification services, referral to substance abuse treatment, and case management services.

The following research studies examined the effectiveness of family in-home support as indicated preventive measures:

1. Henggeler, Melton, and Smith (1992) and Henggeler, Melton, Smith, Schoenwald, and Hanley (1993) evaluated the effectiveness of multisystemic therapy, a family- and home-based treatment designed to intervene directly in systems and processes such as parental discipline, family affective relations, peer associations, and school performance, which are known to be related to antisocial behavior in adolescents.
2. Borduin et al. (1995) replicated the Henggeler et al. (1992) study and examined the use of multisystemic therapy with juvenile serious offenders.
3. Walton, Fraser, Lewis, Pecora, and Walton (1993) compared the effectiveness of an in-home, family-based reunification service with routine out-of-home reunification services in returning children to and keeping them in their homes. Services included transportation, cash assistance, clothing, basic food items, household repairs, and training in such skills as communication, parenting, and anger management.
4. Lutzker, Wesch, and Rice (1984) and Lutzker and Rice (1987) compared the effectiveness of conventional child protection services with that of an in-home ecobehavioral approach to the treatment and prevention of child abuse and neglect. The ecobehavioral intervention was a comprehensive, multiple-setting behavior management program that provided services directly in clients' homes, schools, foster care settings, and day-care settings.
5. Berry (1992) evaluated the effectiveness of intensive family preservation services to prevent out-of-home placement of children in San Francisco and Oakland, California, and to identify family and service characteristics associated with successful family preservation.
6. Haapala and Kinney (1988) examined the effectiveness of an intensive home-based family preservation program designed to treat status-offending youths in danger of imminent out-of-home placement as well as their families.

The following two practice cases were examined:

1. The In-Home Care Demonstration Projects involved three self-care projects for latchkey children and eight in-home care projects to provide intensive, short-term services to families of children at imminent risk of removal from the home.
2. The Intensive Family Preservation Services of the State of Connecticut are targeted to families whose children are at imminent risk of removal from their homes.

Abstracts of the research and practice cases used in this analysis are provided at the end of this chapter.

### Lessons Learned From Evidence Reviewed for Approach 2: Family In-Home Support as Indicated Preventive Measures

The research and practice evidence reviewed in this prevention approach provides for several lessons learned.

1. Although family in-home support is currently a popular prevention approach, the body of relevant research, especially controlled studies, is meager. One barrier to conducting research with experimental designs is the ethical issue of assigning families with identified needs and problems to a nontreatment control group. However, the use of a comparison treatment condition as a control group has been underutilized.
2. Another barrier to research is the complexity and interrelatedness of problems experienced by families receiving in-home support services and the ethical need to respond to all of these problems as soon as possible. It is difficult to formulate a research design that teases out the differing effects of the services and intervention elements to determine whether there is a priority or hierarchy of needs, or that measures interrelationships of specific elements of the intervention and specific outcomes. Thus, only very broad conclusions can be reached about the effects of an intervention.

Level of Evidence for Approach 2: Family In-Home Support as Indicated Preventive Measures

The research and practice evidence for this approach concentrates on family in-home support as indicated preventive measures - comprehensive, intensive, multipurpose services provided in the home and designed to address a range of family problems, typically involving all family members.

The research and practice evidence reviewed indicates the following:

- There is medium evidence that multisystemic therapy, provided in the home, is effective in reducing juvenile criminal activity and rearrest.
- There is medium evidence that multisystemic therapy, provided in the home, is effective in improving family characteristics associated with juvenile antisocial behavior, such as family cohesion and symptomatology.
- There is medium evidence that home-based family preservation services are effective in preventing out-of-home placement and reducing the number of days of placement.

### Suggestions for Future Research for Approach 2: Family In-Home Support as Indicated Preventive Measures

The research and practice evidence reviewed in this prevention approach provides for two suggestions for future research:

1. The level of evidence for the effectiveness of family in-home support studies is not strong, because experimental studies having a common focus are few in number. When a family experiences a serious crisis that requires out-of-home placement of children, there is a possibility that, for some families, the crisis will be resolved or will fade with time, even without treatment. Well-executed intervention research with families in crisis must take into consideration the potential bias of misattributing all or most of the crisis resolution and family stabilization to the intervention, as opposed to the passage of time. To avoid this bias, researchers can include wait-treatment, alternative treatment, or no-treatment comparison groups (Borduin et al., 1995; Henggeler et al., 1992, 1993; Walton et al., 1993). However, many researchers of family in-home support feel that it is unethical to withhold immediate intervention from families who are in crisis and have demonstrable needs. Nonetheless, it is recommended that, when ethically possible, future research on family in-home support should make greater use of comparison groups. Overall, the field of in-home family support can benefit greatly from experimental research designs.
2. Research on family in-home support should measure a range of variables to examine the effectiveness of interventions. Suggested measures include mediating variables (e.g., social support networks and family functioning, conflict, and bonding) and ultimate outcomes (such as family stability, child problem behaviors, staying in school, academic success, prosocial skills, delinquency, and avoidance of out-of-home placement). Research efforts should include multiple data sources, such as parent and child self-reported behavior, observed behavior, and archival record data (Berry, 1992; Borduin et al., 1995; Haapala & Kinney, 1988; Henggeler et al., 1992, 1993; Lutzker et al., 1984).

The following section consists of recommendations, observations, and interpretations made by Expert Panel members concerning the Family In-home Support approach. The basis for these recommendations includes the research and practice evidence reviewed in the Analysis of Evidence section; research and practice evidence not reviewed in this chapter; and the PEPS Expert Panel members' expertise, experiences, and opinions.

### Recommendations for Prevention Approach 2: Family In-Home Support as Indicated Preventive Measures

The Expert Panel's recommendations regarding family in-home support focuses on issues such as family-centered assessments, strength-based assessments, fragmentation of services, neighborhood-based family workers, and a variety of family preservation efforts, as follows:

1. Families should be encouraged to become integral partners in the assessment process. The assessment should include the family's perspectives on the nature of the problems being addressed and the ways in which problems should be solved. The assessment process should reflect families' perspectives about their needs, goals, objectives, and timelines. Assessments and service plans should address the needs of the entire family. Conducting assessments in partnership with families helps to clarify the roles and responsibilities of family members and service providers. It also helps families increase their capacity to manage their own responsibilities.
2. Assessments and service plans should consider the context of the family's community and should include informal supports, such as family members, churches, and neighbors.
3. Historically, assessments have often focused predominantly on the family's problems and deficits and the provision of services to solve those problems. Experience suggests that the usefulness of assessments and subsequent family service plans is maximized when they build upon areas of strength, competence, and capability, as well as address problem areas. Although a family in crisis may have areas of weakness, these areas can be considered opportunities for improvement rather than deficits. Further, it is important to identify and validate the strengths that are helping the family survive. Evaluation of family strengths should include an assessment of both the family's readiness and willingness to change and the parents' capacity to invest in acquiring parenting skills. When a family's strengths are enhanced and weaknesses reduced, the capacity to thrive is enhanced.
4. Families in crisis must often negotiate a maze of complicated and differing health and social service systems when they are least able to identify and gain access to the services they need. These families routinely work with several provider representatives, frequently filling out duplicative agency-specific paperwork. This fragmentation of service systems creates barriers to the formation of effective partnerships. Attrition and recidivism are often related to these barriers, which should be removed wherever possible, with the goal of making integrated and comprehensive resources available for families.
5. Neighborhood-based family workers should be recruited to help families and service providers integrate and manage services. This could enhance the capacity of care providers to form alliances with formal and informal neighborhood-based support networks to strengthen family functioning. It also may help provide ongoing emotional and informational support and consistent relationships.
6. Family preservation programs vary with respect to theoretical orientation, length and intensity of service, and populations served (Henggeler, Schoenwald, Pickerel, Rowland, and Santos, 1994). These variations reflect differences in program goals, including an emphasis on treatment versus direct and support services, such as collaboration with health care, housing, and employment agencies. For example, Nelson, Landsman, and Deutelbaum (1990) concluded, on the basis of a review of 11 studies involving child welfare populations, that intensive family treatment programs appeared to be more effective than crisis intervention and home-based programs. More research should be done on the variations of family preservation to determine what efforts are most successful, and under what conditions.

## Prevention Approach 3: Family Therapy as Indicated Preventive Measures

This approach attempts to prevent substance abuse among children and adolescents by providing family therapy to families with children who have diagnosed behavioral or emotional problems that increase their risk of developing substance abuse-related disorders, with the goal of improving family dynamics and interpersonal behavior.

### Conceptual Framework for Approach 3: Family Therapy as Indicated Preventive Measures

Families experiencing multiple risk factors or high levels of a single risk factor often have poor communication skills, negative perceptions about and behavior toward one another, and other dysfunctional family dynamics. This is especially true of families who have children with behavioral or emotional problems that increase their risk of developing substance abuse problems. As an indicated preventive measure, family therapy helps family members develop interpersonal skills to improve communication among family members and improve family dynamics. This approach can be used to help family members improve their perceptions of one another, change maladaptive functioning, decrease negative behavior, and create skills for healthy family interaction. It can also be used to enhance parenting skills and reduce inappropriate parental control over children.

Although approaches to family therapy differ with respect to theories and goals, they commonly seek to restructure behavior patterns among family members, change members' perceptions of one another, and improve their roles and functions. Generally, family therapy also seeks to improve the awareness and insight of participants, especially regarding dysfunctional and maladaptive interactions and behaviors.

### Overview of the Evidence for Approach 3: Family Therapy as Indicated Preventive Measures

The objectives of the interventions reviewed focused on improving family functioning and reducing children's recidivism and problem behaviors. Expected outcomes for families included increasing mutual positive reinforcement and decreasing maladaptive interaction patterns, improving family dynamics in families with juvenile offenders or adolescents with antisocial behaviors, acquiring skills, improving communication, learning effective discipline methods, and learning self-management skills. Expected outcomes for youth included reducing behavioral and emotional problems and recidivism rates, improving the functioning of juvenile offenders, and preventing initiation of substance use.

The following studies examined the effectiveness of family therapy as an indicated preventive measure:

1. Alexander and Parsons (1973) evaluated the effectiveness of a short-term, behaviorally oriented family intervention for families with delinquent teenagers. The intervention was designed to reduce maladaptive interaction patterns in families, increase mutual positive reinforcement, and reduce recidivism rates among the teenagers.
2. Barton, Alexander, Waldron, Turner, and Warburton (1985) reported on three studies that evaluated the effectiveness of functional family therapy used by undergraduate paraprofessional therapists and foster care case-workers in the treatment of seriously delinquent youth who had recently been released from a State criminal justice institution.
3. Gordon, Arbuthnot, Gustafson, and McGreen (1988) compared the effectiveness of standard probation with a home-based, time-unlimited, behavioral-systems family therapy model in the treatment of juvenile offenders of low socioeconomic status.
4. Szapocznik, Murray, et al. (1989) compared the effectiveness of structural family therapy, psychodynamic child therapy, and a recreational control condition in the reduction of behavioral and emotional problems and improvements in child and family functioning among Hispanic boys who had been diagnosed with opposition disorder, anxiety disorder, conduct disorder, or adjustment disorder.
5. Santisteban et al. (1997) evaluated the effectiveness of brief structural family therapy to prevent drug use initiation among Hispanic and African-American youth.
6. Henggeler et al. (1986) compared the effectiveness of multisystemic family-ecological therapy and an alternative therapy in improving family dynamics in families of juvenile offenders and in improving the behavior problems of these juveniles.
7. Mann, Borduin, Henggeler, and Blaske (1990) evaluated the effectiveness of multisystemic therapy in the treatment of adolescent antisocial behavior by using the therapy to treat "cross-generational coalitions," in which a parent, usually the mother, forms a stable coalition with the child against the other parent in family transactions (as opposed to stable mother-father coalitions).
8. McPherson, McDonald, and Ryer (1983) compared the effectiveness of short-term, intensive family counseling with casework-oriented probation for youthful offenders. The therapy was designed to help participants acquire new skills and ideas, understand and appreciate one another, improve communication, learn effective discipline methods, learn self-management skills, and examine their own and other family members' expectations.
9. Springer, Phillips, Phillips, Cannady, and Kerst-Harris (1992) evaluated the effectiveness of an organized art and play therapy, embedded within peer group and family therapy, on the competencies and problem behaviors of children of individuals with substance abuse problems.

Level of Evidence for Approach 3: Family Therapy as Indicated Preventive Measures

The research evidence for this approach focuses on family therapy interventions for indicated populations - interventions to improve family dynamics and interpersonal behavior in families with children who have diagnosed behavioral or emotional problems that increase their risk of developing substance abuse-related disorders.

The research evidence reviewed indicates the following:

- There is medium evidence that among this population of families, family therapy results in family interaction improvements, such as enhanced parenting skills with adolescents, improved family communication, increased parental knowledge about reducing antisocial behavior in their adolescent children, improved perceptions and attitudes of parents and adolescents about each other, and reductions in inappropriate parental control over adolescents.
- There is strong evidence that among this population of families, family therapy reduces the rates of recidivism in delinquent teenagers.

Abstracts of the research used in this analysis are provided at the end of this chapter.

### Lessons Learned From Evidence Reviewed for Approach 3: Family Therapy as Indicated Preventive Measures

The research reviewed in this prevention approach provides for several lessons learned:

1. Research demonstrates that family therapy is an effective resource for improving family functioning, increasing parenting skills, and decreasing recidivism of juvenile offenders (Alexander & Parsons, 1973; Barton et al., 1985; Gordon et al., 1988; Henggeler et al., 1986; Mann et al., 1990; Santisteban et al., 1997; Szapocznik, Murray, et al., 1989).
2. Research demonstrates that family therapy can be embedded within multicomponent prevention efforts (Gordon et al., 1988; Springer et al., 1992). Although it has not yet been the focus of research, family therapy can be a component in prevention efforts that include in-home family support and school-based problem-solving counseling.
3. For the most part, empirical investigations of family therapy have focused on families with adolescents, many of whom are juvenile offenders (Alexander & Parsons, 1973; Barton et al., 1985; Gordon et al., 1988; Henggeler et al., 1986; McPherson et al., 1983). These youth are often clinically challenging and have behavioral disorders of moderate to severe intensity. The applicability of family therapy with younger children who have less severe behavior problems has not been as thoroughly investigated, but the findings of Szapocznik and others are encouraging.

### Suggestions for Future Research for Approach 3: Family Therapy as Indicated Preventive Measures

The research reviewed in this prevention approach provides for several suggestions for future research.

1. Except for the work of Szapocznik, there has been little evaluation of, and therefore more research is needed on, the cultural appropriateness of family therapy programs.
2. More research based on experimental designs is needed to evaluate the use of family therapy as an indicated preventive measure with regard to substance abuse (Alexander & Parsons, 1973; Szapocznik, Murray, et al., 1989).
3. Additionally, research should use a wider variety and a greater number of sources for data collection. These include self-reports of children and family members, direct observations of parent-adolescent interactions, and school and teacher reports, as well as information from collateral individuals, testing batteries, archival records, and court reports and records (Alexander & Parsons, 1973; Barton et al., 1985; Klein et al., 1977; Santisteban et al., 1997; Springer et al., 1992; Szapocznik, Murray, et al., 1989).
4. Additional research is needed on the impact of family play therapy on child outcomes with regard to substance abuse prevention (Springer et al., 1992).
5. Research is needed on the use of neighborhood-based family workers in outreach engagement and retention of families in therapy.
6. In the substance abuse and mental health fields, there is substantial literature on the effectiveness of various types of family therapies that is beyond the scope of this guideline. Most of these therapies can be described as traditional psychotherapeutic therapies. However, there are several nontraditional family-centered therapies, often spiritually based, such as interventions delivered within Native American and other ethnic and cultural groups. These nontraditional family therapies should be subjected to research regarding their effectiveness and implementation.
7. Research has not yet explored ways that family therapy can be joined with other prevention efforts and the ways in which the effectiveness of prevention can be enhanced through such multicomponent activities.

The following section consists of recommendations, observations, and interpretations made by Expert Panel members concerning the Family Therapy approach. The basis for these recommendations includes the research and practice evidence reviewed in the Analysis of Evidence section, research and practice evidence not reviewed in this chapter, and the PEPS Expert Panel members' expertise, experiences, and opinions.

### Recommendations for Prevention Approach 3: Family Therapy as Indicated Preventive Measures

The Expert Panel's recommendations on family therapy focus on issues such as interagency collaboration, program engagement and retention, cultural context, and the appropriateness of including young children.

1. Because families in crisis are likely to receive services from multiple agencies, family therapy providers should be linked with social and other service agencies through interagency collaboration and coordination and integrated case management - systemic strategies that address the linkages among programs, agencies, and departments. Regardless of the specific model, interagency collaboration and coordination may be facilitated by formal or informal interagency agreements, including memoranda of understanding, case management meetings, and regular multidisciplinary interagency training. A special contract (e.g., a qualified service organization agreement) is a common method for agencies to document their agreement on the provision of services, including the development of joint referral, intake, and assessment procedures.
2. Family therapy is still viewed negatively by people of some ethnic groups, socioeconomic strata, and regions. Thus, their engagement and retention in family therapy can be challenging but can be enhanced by reducing negative attitudes toward therapy and by labeling the program in a culturally consonant way. When designing therapy-based research and interventions, researchers and providers should educate the target population and the community about the value of family therapy and demystify the therapy process. Neighborhood volunteers and community outreach workers can be trained to provide lectures on depression, anxiety, substance abuse, and child problem behaviors. Working in close partnership with churches, schools, and community centers, outreach workers may be able to engage families skeptical of family therapy. It is not necessary to make potential participants understand therapeutic jargon. Rather, interventions can be packaged in ways that are acceptable to community members.
3. Practitioners should be knowledgeable and competent in the cultural values, beliefs, and traditions of the families they serve and knowledgeable about the resources available in the community in which the family lives.
4. Family therapy that requires a participant's understanding of complex family and interpersonal dynamics may not be developmentally appropriate for some young children. Therefore, the selection of family therapy and other interventions should take into consideration the appropriateness of specific interventions for child participants.

## General Suggestions for Future Research for Family-Centered Prevention Approaches

All of the Expert Panel suggestions on future research mentioned earlier are specific to one of the three prevention approaches evaluated in this chapter. The following suggestions are applicable to more than one prevention approach:

1. Much family-centered prevention research has been conducted in university-based settings. There is a need to develop, assess, and evaluate procedures for dissemination of research to the community.

2 Most family-centered prevention research has been conducted in urban environments. There is a need for research and practice evidence to evaluate whether programs can be effectively implemented in suburban and rural areas. For example, there is a need to determine whether such programs can overcome rural logistical problems, such as transportation difficulties and a lack of trained professionals.

3 The outcomes and conclusions reached in the studies reviewed in this chapter are primarily based on White families of mixed socioeconomic status. The generalizability of the conclusions described in this chapter to diverse ethnic and cultural groups is unknown. In addition, although several important research studies have been completed on family-centered interventions for specific cultural groups, additional studies are needed for African-American, Hispanic, Asian-American, and American Indian populations and their subcultures. Research should be conducted to evaluate the differences between urban and reservation-based American Indians.

4 The effectiveness of family-centered prevention interventions needs to be examined separately for girls and boys. Just as there may be different developmental pathways to antisocial behavior and substance abuse for girls and boys, interventions may also be differentially effective. Thus, research should examine the effectiveness of and need for gender-specific prevention interventions.

5 There is a need to examine mechanisms related to effective recruitment, engagement, and retention for family-centered interventions. Also, research should address the generalizability of family-centered outcomes to contexts such as schools, churches, and recreation centers.

6 Although direct behavioral observations can be expensive and labor intensive, family-centered prevention researchers should consider including behavioral observation in natural settings, such as the home, as well as in clinical and other structured settings.

7 There is a need to evaluate the value and role of formal and informal social support systems in a community-based context with regard to family-centered prevention interventions.

8 Both researchers and practitioners should investigate the applicability and efficacy of family-centered prevention approaches for families at various levels of functioning. Results of such research should help to determine the most efficient and cost-effective intervention approach for families at different levels of functioning. For example, it would be useful to compare family therapy, family skills training, and parent training as selective and indicated preventive measures.

9 There is a need for continued research regarding risk and protective factors and resiliency. Substantial research has been conducted on risk factors, but less has been conducted on protective factors. Although resiliency appears to be a promising area of prevention and research, it is underresearched. (Chapter 5 provides a more detailed description of resiliency and related research issues.)

10 With regard to research on antisocial and other problem behaviors, delinquency, and associated substance use, there is evidence for the following:
  a. Early-onset antisocial behavior is a better predictor of continued antisocial behavior than is late-onset antisocial behavior, but more for boys than for girls. Early substance use, however, predicts continuity in both sexes.
  b. Most evidence suggests that antisocial and other problem behaviors precede later substance use rather than the reverse, at least in those youngsters who eventually engage in both.
  c. Additionally, there is evidence that progression in one category of undesirable behavior, such as substance use, is associated with an increased likelihood of persistence in other categories of behavior, such as delinquency (Loeber, 1988). Therefore, there is a need for extended longitudinal studies that evaluate children who experience antisocial and other problem behaviors during their very early years (such as during preschool and elementary school) and that continue to follow them through their later adolescent years. Such studies could help determine the critical pathways and developmental progression that lead from early conduct problems to more serious antisocial behaviors and substance use problems. Research has not adequately determined why certain children have conduct problems very early in life and "grow out of it," whereas a small percentage progress to worse behavior and to substance use.

11 Research should also evaluate the interrelationships among serious childhood behavioral problems and disorders, family and ecological risk and protective factors, and the later emergence of substance use disorders.

12 It is typical for children with antisocial and other problem behaviors to be identified and evaluated only once, while they are symptomatic. However, most of these children will "outgrow" such problems. As a result, children who experience temporary or situational antisocial and other problem behaviors are often lumped together with those who experience "stable-pervasive" problems (i.e., problem behaviors that stabilize at a very young age and progressively worsen over time and throughout developmental stages). Therefore, there is a need for research to determine at what point between preschool and late adolescence stable-pervasive antisocial and other problem behaviors best predict such problems and substance abuse among young adults.

13 Certain types of prevention interventions are more effective for children with particular types of behavioral problems and families, for children who are at specific stages of development, and for those who have specific risk and protective factors. Therefore, research should continue to explore the most effective prevention interventions that match the specific needs of the target populations.

14 Perhaps the most important overall recommendation for future research on family-centered prevention approaches concerns the need for longitudinal studies to evaluate the effects of changes in child and family problem behavior on subsequent substance abuse. Most of the studies of children's antisocial and other problem behaviors that were available for review focused on immediate outcomes regarding the problem behaviors of the child and the family. Some follow-up studies were conducted to determine whether outcomes were sustained a few years postintervention. Additionally, a line of etiologic research examined the connections and associations between childhood behavioral issues and later adolescent substance abuse. These etiologic studies typically attempted to determine which clusters of risk factors and associated child and family behaviors predicted adolescent substance abuse.

The interpretation, and in some cases the purpose, of many of these studies was predicated on the hypothesis that the intervention would result in a decline in children's antisocial and other problem behaviors and that such changes would lead to the prevention, reduction, or elimination of substance abuse in later adolescence or beyond. However, this hypothesis has not been adequately tested, in part because the children were typically not followed over the course of several years. Therefore, there is a tremendous need to conduct longitudinal studies designed specifically to examine the relationships between interventions devised to treat child problem behaviors and subsequent prevention, reduction, or elimination of substance abuse during adolescence and later life.

## General Recommendations for Practice for Family-Centered Prevention Approaches

Most of the Expert Panel recommendations described previously are specific to one of the three prevention approaches evaluated in this chapter. The following recommendations, suggestions, and interpretations are applicable to more than one prevention approach:

1. Family-centered prevention services are less likely to be successful when families have significant unmet biopsychosocial needs, such as those relating to food, shelter, employment, literacy, and physical and mental health. Indeed, families need to have their basic needs met both during and after the intervention to increase chances for success. Thus, whether through direct provision or through collaborative relationships with service providers, prevention practitioners have a responsibility to provide those services or the referral information and referral followup that will ensure that families receive the biopsychosocial services they require.

2 Overall, antisocial and other problem behaviors fit on a continuum from mild and occasional to severe and chronic. For a child with these problem behaviors, there are typically periods of turbulence and intervals without problem behaviors. Further, such problems exist in family and community contexts that range from healthy to unhealthy and from supportive of prevention goals to unsupportive. Therefore, it is unrealistic to expect that a short-term (e.g., 10- to 14-session) intervention involving parent training, family skills training, or family therapy will provide a "single-shot cure" for children with conduct disorder, oppositional defiant disorder, or other problems. This is especially true for children with severe and chronic behavioral problems in difficult family and community contexts. Rather, it is more realistic to apply such interventions in repeated and booster sessions that are tailored to the major stages of a child's development. Likewise, it is advisable to consider using other types of interventions before, during, after, or in place of family-centered approaches, depending on the specific needs of the family and child. These may include school-based student counseling, psychiatric interventions, self-help programs, and educational services.

3 Whenever possible, prevention interventions should be provided in settings and locations that are comfortable, natural, and accessible to parents and children. Services should be provided in the community where the target population resides and in locations that are familiar to and frequented by potential participants. It is ideal to bring the intervention to the setting where the target group exists, such as schools, jails, welfare centers, workplaces, homes, churches, and community centers.

4 Most approaches to the prevention of substance abuse, such as school-based and community-based interventions, are compatible with and can include family-centered interventions. For example, school-based interventions can easily be combined with parent and family skills training and even family therapy interventions. Doing so will help to reduce family-related risk factors and increase resilience factors empirically related to substance abuse.

5 Family-centered interventions can be made more attractive and accessible by providing vital services that remove barriers to participation such as transportation, child care, and meals.

6 Family-centered interventions should be embedded within, and sanctioned by, the community. This may involve conducting community outreach and educational efforts with community leaders such as ministers, physicians, and educators and conducting outreach focus groups and educational efforts with consumers.

7 Especially when involved in community education, prevention experts should modify their roles and change the way they view themselves. Rather than assuming authoritarian roles of those who identify problems in others and provide therapeutic services to solve these problems, professionals should assume the roles of "information provider" and "resource expert." That is, they should provide information to families about a variety of health and mental health issues, help families learn to recognize the need for professional assistance when there is a problem, inform them about options and resources in the community, and teach them how to gain access to these resources. In this way, professionals can help families make informed decisions rather than imposing decisions upon them.

8 There is a tremendous need to build and sustain active partnerships between prevention researchers and practitioners. These partnerships must involve the transfer of skills, knowledge, and expertise between both groups. Transfer of skills and knowledge from researchers to the community should be a capacity-building process that allows the community to develop the mechanisms required to conduct long-term research studies and to establish ongoing family-centered prevention programs. At the same time, knowledge transfer from the community to researchers should include having local community experts, residents, parents, and consumers participate in design and implementation of research. (See the discussion of evaluation in chapter 4.)

## Chapter 3 Appendix: Research and Practice Evidence Abstracts

To understand the conclusions presented in this guideline, the strength of the evidence supporting those conclusions, and the evidence-based lessons learned, it is important to examine the basis on which those evaluations were made. Thus, this section presents a summary of each research study and practice case, including the study design, where appropriate; the overall intent of the study or program; and selected findings or results.

The summaries present those outcomes most relevant to the prevention approach in question, rather than all of the research and practice outcomes. In general, the quantitative outcomes reported as significant are statistically significant; the exact effect size is not reported. In most studies, evaluations were conducted at baseline and postintervention. Some also involved followup evaluations, defined here as evaluations conducted after a postintervention evaluation. The summaries do not include a critical analysis of study design biases (for research studies) or process evaluation biases (for practice cases), or of program implementation. Analysis of these and other similar characteristics were the basis for deciding whether or not a research study or practice case constituted evidence for this guideline. The summaries simply provide a "snapshot" of the research or practice evidence critically analyzed by the Expert Panel. Where possible, the timeline or chronology of the intervention and study are included in the abstract. When available and relevant, the following information is included in the summaries:

1. Ethnicity, age, and sex of study participants.
2. Inclusion criteria (e.g., students with conduct disorder).
3. Purpose and design of the study.
4. Nature of the intervention and control or comparison conditions.
5. Amount of intervention exposure (i.e., duration and number of sessions).
6. Number and interval of evaluations (e.g., baseline and followup evaluations).
7. Descriptions of what was measured at evaluations.
8. Selected outcomes.

### Abstracts for Prevention Approach 1: Parent and Family Skills Training

The Expert Panel recommended presenting research and the practice evidence under Approach 1 for Clusters 1 and 2 separately. The Expert Panel also recommended that the evidence be categorized according to child and parent involvement. Therefore, the research and practice evidence for Prevention Approach 1 is organized as follows:

- Research Evidence Reviewed for Approach 1, Cluster 1
  - Parent training without child involvement.
  - Parent training plus family skills training.
  - Parent training with separate child training plus family skills training.
- Practice Evidence Reviewed for Approach 1, Cluster 1
  - Parent training without child involvement.
  - Parent training with separate child training.
  - Family skills training.
- Research Evidence Reviewed for Approach 1, Cluster 2
  - Parent training without child involvement.
  - Parent training with separate child training.
  - Family skills training.
  - Parent training plus family skills training.
- Practice Evidence Reviewed for Approach 1, Cluster 2
  - Family skills training.
- Collateral Evidence Reviewed for Approach 1 (Clusters 1 and 2)

#### Research Evidence Reviewed for Approach 1, Cluster 1

The following are abstracts of research studies that constitute the research evidence for parent and family skills training as selective and/or universal preventive measures. The research evidence for Cluster 1 is organized according to child and parent involvement: parent training without child involvement, parent training plus family skills training, and parent training with separate child training plus family skills training.

##### Parent Training Without Child Involvement

###### Felner et al. (1994)

Felner et al. (1994) evaluated the effectiveness of a work-site-based parenting program designed to improve parent-child interactions by increasing the knowledge and improving the attitudes and discipline skills of parents. In this quasi-experimental study with a rotating pretreatment and posttreatment design, 191 parents voluntarily participated in 24 1-hour sessions twice weekly for 12 weeks. Most subjects (96 percent) were full-time employees living near a major metropolitan area in the Midwest and had preschool- and school-aged children. The parent training course sought to modify risk and protective factors for substance abuse by improving parents' interactional and parenting skills, increasing support networks to address both parenting stress and conflicts between work and family roles, and expanding parents' knowledge of and encouraging the adoption of healthy attitudes and behaviors toward substance abuse. Measurements at baseline, posttreatment, and 9-, 18-, and 30-month followup evaluations focused on changes in child behavior problems and parental stress, interactional skills, and knowledge of child development. Program participation was described as either high program exposure (80 percent participation or greater) or low program exposure (less than 80 percent participation).

Findings:

1. Parents with high program exposure rated child behavior problems "decreased" and positive behavior and parenting practices and knowledge "increased." These improvements were maintained throughout the 18-month followup period. Those with low program exposure reported no improvement in child behavior.
2. Parents with high program exposure reported reductions in stress and depression throughout the 9-month followup period. Parents with low program exposure did not report these reductions.
3. Parents with high program exposure rated the impact of child problem behavior and prosocial behavior more positively than did low-exposure parents.
4. Program attendance was greater among parents who reported higher preprogram levels of social isolation and child behavior problems.

###### Myers et al. (1990)

Myers et al. (1990) conducted a quasi-experimental field test of a culturally appropriate cognitive-behavioral parenting skills building program. Two cohorts of inner-city African-American parents and their 1st- and 2nd-grade children participated in the program (65 treatment and 34 control dyads per cohort). The 15-session model program incorporated a range of historical and contemporary sociocultural issues facing African-American families into the teaching of basic behavioral child management strategies and skills. The intervention included lectures, skills demonstrations, and parent role playing to teach parents how to describe and quantify child behaviors and to use behavior-specific praise; mild social disapproval; and ignoring, time out, and special incentives as behavioral consequences for respectful and disrespectful child behaviors. Evaluations at baseline, postintervention, and for Cohort 1 at 1-year followup focused on the quality of the parent-child relationship, parenting practices, and child behavior problems and social competencies.

Findings:

1. Improvements for Cohort 1 included reduction in subtle forms of parental rejection, increased reports of improved parent-child and family relationships, and reduced withdrawal and hyperactivity (in boys) and sexual issues (in girls).
2. Followup at 1 year indicated maintenance of reductions in parental rejection, although there was a regressive trend toward using earlier and more coercive parenting practices.
3. Reductions in child behavior problems were maintained, and there were additional significant increases in the communicativeness of boys.
4. Improvements for Cohort 2 included reductions in both subtle and hostile-aggressive forms of parental rejection, decreases in the use of corporal punishment, increases in verbal acknowledgment or praise, reductions in delinquent behaviors (e.g., lying, stealing) in both boys and girls, and increases in social competency for girls.

###### Guerney (1977)

Guerney (1977) evaluated the effectiveness of a skills training program designed to improve psychological helping skills for foster parents of children aged 5 to 12 years. Approximately 75 percent of the foster children were White (the ethnic composition of the rest of the children was not described); about 10 percent were considered emotionally disturbed or mildly retarded. The families came from small towns, rural settings, and from a large metropolitan area. In this nonexperimental-design study with nonrandom assignment, 57 foster parents who were willing but unable to participate in the program were compared with 75 foster parents who participated in a skills training program 2 hours weekly for 10 weeks. Parental acceptance of and sensitivity to children, and desirable and undesirable verbal communication skills were measured at baseline and posttreatment.

Findings:

- Foster parents in the treatment group (but not the comparison group) showed posttest improvements as follows:

1. Increase in attitudes of acceptance toward the foster children in their care.
2. Increase in the acquisition of parenting skills defined as desirable.
3. Decrease in parenting responses defined as undesirable.

###### Guerney and Wolfgang (1981)

In a nonexperimental study, Guerney and Wolfgang (1981) evaluated a skills training program for foster parents that focused on the development of skills for child management, empathy, relationship development, and understanding of children's needs and development. The 10 program sessions of the Foster Parent Skills Training program used demonstrations and role playing and other types of practice as the predominant tools. Participation in the program was by self-selection at some agencies and by foster agency staff at other agencies, based on their determination of foster parents who most needed or were most likely to attend the programs. Control groups included persons who had agreed to participate but for practical reasons could not do so. The number of parents participating in the study was not specified, but they were referred by several foster agencies. In this multiphase study, evaluation was by direct interviewing and questionnaire. Baseline and posttraining evaluations were conducted at all sites (number not provided). Some sites included a comparison group.

Findings:

- The program consistently resulted in the following:

1. Increased parental accepting attitudes toward children.
2. Increased parental ability to provide responses to children in hypothetical situations that were consistent with the skills taught and the goals of promoting child and parent-child relationship development.
3. Increased parental ability to reduce the use of parental responses considered unconstructive or destructive in their impact on children. These gains were maintained at 9-month followup.

###### Thompson et al. (1993)

Thompson et al. (1993) evaluated the effectiveness of a parenting program developed to teach middle and lower income parents child management skills to decrease their children's developmental, learning, and behavioral problems. In this nonexperimental-design study, 34 parents participated in eight weekly 2-hour sessions that included lectures, discussion, role playing, modeling, assignments, and videotapes. The baseline, posttreatment, and 3-month followup measures focused on child problem behaviors, parental attitudes, and parental problem-solving confidence skills.

Findings:

1. Improvement was noted in the primary measures, including a decrease in the number and frequency of child behavior problems and an increase in parental problem-solving confidence and personal control.
2. Improvements were maintained at 3-month followup.
3. No significant differences over time were noted between middle and lower income parents in reported changes.

###### Knapp and Deluty (1989)

In an experimental study by Knapp and Deluty (1989), one of two 8-week behavioral parent training programs was provided to each of 40 mothers who responded to announcements of a behavior management program. Most of the mothers were White; 22 were of middle socioeconomic status, and 18 were of low socioeconomic status. Approximately half of the mothers were taught parenting techniques through the use of modeling and role playing, and the others were taught through readings, brief review testing, and discussions. Baseline evaluations included scored observations of parent-child interactions that focused on negative child behavior (noncompliance and inappropriate behavior) and positive parent behavior (good commands, attention, praise, and ignoring). Evaluations also included tests that focused on the mothers' perceptions of their children's behavior, adaptability, acceptability, demandingness, mood, distractibility, and hyperactivity as well as on children's perceptions of changes in their mothers' behavior after training. The evaluations were conducted at baseline, postintervention, and 2 months postintervention.

Findings:

1. After training, significant decreases in behavior problems from baseline levels were reported by mothers of middle, but not lower, socioeconomic status.
2. Although the initial gains were minimal, the role-playing mothers of lower socioeconomic status reported maintenance of gains at the 2-month followup, whereas those of the same status in the reading and discussion group did not.
3. During structured observation, mothers of lower socioeconomic status in the modeling and role-playing group more often used the skills they had been taught than did mothers of lower socioeconomic status in the reading and discussion group.

###### Wolchik et al. (1993)

Wolchik et al. (1993) evaluated the effectiveness of a parent-based intervention designed to improve psychological adjustment in children of divorced mothers. In this experimental-design study, 70 divorced mothers were randomly assigned to a 12-session parenting program (10 weekly group sessions and 2 individual sessions) or to a waiting list. The intervention was designed to promote acquisition and/or enhancement of parenting skills that would improve mother-child relationships and discipline methods, minimize divorce-related trauma, increase contact with fathers, and encourage support from other adults. Baseline and 12-week posttreatment evaluations were based on children's and mothers' reports on parent-child relationships and children's reports on discipline and psychological adjustment.

Findings:

1. At posttest, program participants reported higher quality mother-child relationships and better discipline, fewer divorce-related traumas, and better mental health outcomes than did control subjects.
2. Mothers reported more positive effects than did children; families with poorest initial levels of functioning also reported greater program effects.
3. Improvements in mother-child relationships partially mediated the effects of the program on the children's mental health.

##### Parent Training Plus Family Skills Training

###### Catalano et al. (1995)

Catalano et al. (1995) compared the effectiveness of methadone maintenance treatment alone (control group) and that of a methadone maintenance treatment with a theory-based parent training component (intervention group) designed to increase relapse prevention skills, improve parenting skills and child skills and behavior, and reduce parent and child drug use. In this experimental-design study, 144 parents in methadone maintenance treatment for opiate addiction (most of whom were White females) were randomly assigned to one of the two conditions (with and without parent training). The parent training intervention was delivered in 33 parent training sessions conducted over 16 weeks; 12 of the sessions included the children. Training was reinforced through 9 months of home-based case management. Baseline and posttreatment measures focused on refusal skills, relapse coping skills, effects on family functioning, and parent drug use.

Findings:

1. Parents in the intervention group displayed higher skill levels than did control parents during role playing with respect to drug refusal and relapse coping skills. However, they were no more likely to believe that they would remain heroin-free than were control parents.
2. Families in the intervention group held more family meetings to discuss family leisure activities than did families in the control group, but they did not have more family discussions on drug issues or family problems.
3. At posttreatment, intervention subjects used opiates less frequently than did control subjects, but no differences were found between groups on the prevalence of alcohol use and the use of drugs other than heroin.
4. At posttreatment, no differences were found between groups in family bonding, family conflict, or domestic conflict.

###### Spoth et al. (1995), Kosterman et al. (1996, 1997)

Spoth and colleagues (1995) conducted a series of studies as part of a large-scale family-focused preventive intervention project (Project Family) to assess the efficacy of the Preparing for the Drug (Free) Years program (PDFY) and the Iowa Strengthening Families program. Spoth et al. reported on parenting outcomes of PDFY, a theory-based family skills training intervention designed to prevent adolescent substance abuse and other problem behaviors. The 209 rural families participating in an initial outcome study were randomly assigned to a group receiving PDFY or to a waiting-list control condition. Parents in the intervention group attended a five-session multimedia skills training program, including one session on peer resistance skills that was also attended by their children. This experimental-design study included self-reported and observational measures at baseline and posttreatment regarding parenting skills specifically targeted by the intervention (communication and management specific to substance use, helping adolescents express feelings, and family involvement) as well as general child management skills. Kosterman et al. (1996, 1997) examined outcomes specific to each of the five PDFY sessions.

Findings:

1. At posttest, significant differences were noted between mothers and fathers in the intervention group and those in the control group for parenting behaviors directly targeted by the intervention and for general child management skills not directly targeted by this intervention.
2. In addition to the intervention, individual differences in readiness for parenting change, parenting self-efficacy, and parental attendance predicted changes in parenting behaviors targeted by the intervention.
3. More parents in the intervention group than control parents provided reinforcement to their children for prosocial behavior, monitored their children's whereabouts, and reported increased family involvement with their children, both in discussing family issues and in pleasurable activities.
4. Differential attendance at each of the sessions was noted among parents in the intervention group. Those who attended specific sessions experienced more improvements in behaviors targeted by these sessions than did the intervention group as a whole.
5. More mothers and fathers in the intervention group than in the control group demonstrated improved relationship quality and more proactive communication. Mothers were also observed to have less negative interactions with their children.

###### Spoth and Redmond (1996), Spoth, Redmond, et al. (1997)

In an additional analysis of the PDFY program, Spoth and Redmond (1996) and Spoth, Redmond, et al. (1997) examined three interrelated models of theory-based mechanisms of change in selected outcomes, incorporating intervention parameters such as session attendance level.

Findings:

1. Maternal level of intervention attendance had direct effects on child management and mother-child affective quality at posttest. Father's level of intervention attendance had direct effects on child management.
2. Mothers' and fathers' parent-child affective quality had direct effects on child management behaviors. Additionally, there was evidence of a reciprocal effect of child management behaviors on parent-child affective quality.
3. Attachment to parents and peer prosocial norms had direct effects on young adolescents' alcohol refusal skills. Indirect effects of parent intervention attendance level on young adolescents' alcohol refusal skills were also in evidence.
4. Family member attendance had a direct effect on young adolescents' attachment with parents; collectively, attachment with parents and peers' prosocial norms had a similar effect on behavioral tendency toward alcohol abstinence at posttest, as did the pretest level of behavioral tendency toward alcohol abstinence.
5. The quality of young adolescents' affectional relationship with parents and prosocial peer affiliation had a significant effect on these young adolescents' sense of mastery and self-esteem.

###### Spoth (in press); Spoth, Redmond, and Shin (in press); Spoth, Redmond, Shin, and Huck (in press); Spoth, Reyes, and Redmond (1997)

Spoth (in press); Spoth, Redmond, and Shin (in press); Spoth, Redmond, Shin, and Huck (in press); and Spoth, Reyes, and Redmond (1997) evaluated the effectiveness of a family competency training program designed to enhance protective parent-child interactions and to reduce children's risk for early substance use initiation. In this experimental-design replication of an earlier study by Spoth and colleagues, 667 rural families with 6th grade students from 33 schools were assigned to one of two family-focused prevention intervention conditions or to a minimal-contact control group. The interventions examined were the five-session PDFY program and the seven-session Iowa Strengthening Families program (ISFP).

Findings:

1. Mothers in the intervention group scored significantly higher than control-group mothers on all three parenting outcome measures examined (intervention-targeted parenting behaviors, general child management, and parent-child affective quality).
2. Fathers in the intervention group scored significantly higher than control-group fathers on the measures of intervention-targeted parenting behaviors and general child management.
3. Both PDFY and ISFP had direct effects on intervention-targeted parenting behaviors, which in turn directly impacted parent-child affective quality and effective child management. PDFY and ISFP also showed significant indirect effects on these two parenting outcomes.
4. Family intervention attendance showed a direct effect on parent-child affective quality, which in turn served to reduce young adolescent oppositional behaviors. Through the effect of improved parent-child affective quality, young adolescent's sense of mastery also served to reduce oppositional behaviors.

##### Parent Training With Separate Child Training Plus Family Skills Training

###### Kumpfer and DeMarsh (1987)

Kumpfer and DeMarsh (1987) compared the effectiveness of three parent-child-focused family-based prevention conditions for reducing the substance abuse risk status of 60 children living with a substance-abusing parent(s). The three conditions consisted of a 14-week parent training program alone, parent training plus a 14-session children's skills training program, and parent and child skills training plus a 14-week family skills training program. In this quasi-experimental dismantling study with random assignment, baseline and posttreatment measurements focused on child problem behaviors, child-parent interactions, and parental behaviors and attitudes.

Findings:

1. All three conditions had significant positive effects, primarily matching each intervention's objectives.
2. The combining of two and three programs had a cumulative effect. Thus, the primary impact of parent training was improvement of the child's targeted negative behaviors, that of children's skills training was an increase in child prosocial behaviors, and that of parent training plus children's skills training was more positive social interactions. The cumulative impact of two or more programs was greater than the impact produced by any program alone.
3. The combination of parents' and children's skills training plus family skills training resulted in the above-mentioned effects, as well as a decrease in parents' drug use in the presence of their children; a decrease in parental depression; an increase in parenting enjoyment; and an increase in family cohesion, adaptability, expressiveness, communication, social networking, and participation in family activities.
4. The combination of parent training, children's skills training, and family skills training was more effective than were the other two conditions with regard to improving the mental status of parents and children, decreasing children's risk behaviors, improving the family environment and parent-child relationship, improving the children's relationships with peers, and enhancing school achievement.
5. Only the combined parent, children's skills, and family skills training condition produced significant decreases in substance use by youth and parental improvements in the parent-child relationship.

###### Kumpfer et al. (1991)

Kumpfer et al. (1991) evaluated the effectiveness of a parent-child-focused family skills training program for reducing the substance abuse risk status of children in 49 African-American families in rural Alabama living with a substance-abusing parent(s). Most of the children were between the ages of 6 and 9 years. The parents were mostly single mothers living in poverty. The nonexperimental study included comparing the effectiveness of the program for two clusters of the intervention group: high- and low-level substance users. The 14-week family skills training program was comprised of behavioral parent training sessions, separate children's training sessions, and joint parent and child training sessions. The interventions were designed to decrease children's problem behaviors, improve children's emotional status and prosocial skills, and improve parenting skills and family environment and function. Baseline and posttreatment measurements focused on child problem behaviors, child-parent interactions, and parental behaviors.

Findings:

- After the intervention, the following were observed:

1. Parents with high-level substance use reported a decrease in family conflict and drug use, both in and outside of the home.
2. Parents with low-level substance use reported an increase in family organization, and their children showed a decrease in obsessive-compulsive behavior.
3. All of the children experienced improvements in measures of externalizing, aggression, delinquency, and hyperactivity.

###### Aktan et al. (1996)

Aktan et al. (1996) evaluated the effectiveness of the Safe Haven program, a family skills training program for inner-city African-American families intended to reduce risk factors for substance use in families in which one parent is known to abuse substances. The program consists of concomitant parent training and children's skills training, followed by family skills training classes. This repeated-measures, quasi-experimental study with pre- and posttest design involved 88 parents and 88 children (aged 6 to 12 years) participating in 12 weekly structured sessions and a nonequivalent comparison group. Baseline and posttreatment parent and child interviews focused on parenting efficacy and bonding with children, children's negative and positive behaviors and school performance, children's school bonding and association with positive peers, family cohesion, family communication, family expressiveness, and family organization. Analyses included a comparison of treatment effects on a group of parents who were heavy users and light users of alcohol, tobacco, and illicit drugs.

Findings:

1. The program had some positive effects on all parents, children, and families, but more reductions in risk factors and increases in protective factors were noted in children whose parents were heavy users than in those whose parents were light users of substances.
2. Parents in both the heavy-use and light-use groups reported a drop in illicit drug use in the family and a reduction in their own drug use.
3. The overall sample of parents and the heavy-use group reported decreases in depression.
4. The overall sample of parents and the heavy-use group reported significant improvements in their perceived efficacy as parents.
5. The heavy-use group reported an increase in the amount of time spent with their children.
6. Children demonstrated reduced aggression and hyperactivity and increased school bonding and time spent on homework.
7. The primary treatment effect on the family environment was improved family cohesion.

#### Practice Evidence Reviewed for Approach 1, Cluster 1

The following are abstracts of practice case studies that constitute the practice evidence for parent and family skills training as a selective and/or universal preventive measure. This practice evidence is organized according to child and parent involvement: parent training without child involvement, parent training with separate child training, and family skills training.

##### Parent Training Without Child Involvement

###### Kansas Family Initiative

The Kansas Family Initiative was a statewide prevention effort designed to help parents learn about substance abuse risk factors, develop a family position on alcohol and illicit drugs, learn techniques for alcohol and other drug refusal, manage family conflicts, and strengthen family bonds. Based on the Preparing for the Drug (Free) Years curriculum, the five-session program was delivered to parents by at least 500 volunteers who were certified through a 3-day Training of Trainers (TOT) workshop. Reports were developed regarding the impact of the training on parents and the trainers. For parents, baseline, posttreatment, and 3-week followup measures focused on curriculum content, attitudes, program usefulness, home implementation, and skills learned. For trainers, measures focused on knowledge and skills acquired and level of confidence in the material being presented.

Findings for parents:

1. Positive attitudes about the program and its usefulness were reported by 94 percent of parents at posttest and 91 percent at followup.
2. The ability to implement the skills learned in training at home was reported by 90 percent of parents at posttest and 84 percent at followup.
3. Gains in knowledge and skills based on chapter 3 of the curriculum (How to Say No) were reported by 22 percent of participants, and 16 percent reported such gains based on chapter 1 (Risk Factors).

Findings for trainers:

1. Positive attitudes about the program and its usefulness were reported by 96 percent of trainers at posttest and 95 percent at followup.
2. Confidence in their ability to present the curriculum was reported by 84 percent of trainers at posttest and 86 percent at followup.

###### Parenting for Prevention

The Parenting for Prevention program of the King County, Washington, Department of Alcohol and Substance Abuse Services is a multiagency parenting education and training program designed to reduce risks associated with compromising the health and protection of children, assist parents with child-rearing challenges through effective parenting, and promote their bonding with families and the community. This parent training curriculum focuses on positive discipline, effective family communication, child growth and development, pride in cultural heritage, development of healthy self-esteem in children, and substance abuse awareness. The number of sessions ranged from 10 to 13, each generally lasting 2 hours or longer. A total of 214 participants attended two or more classes, and 180 completed the program. A one-group pretest and posttest nonexperimental design was employed. Evaluation measures focused on project implementation, participant characteristics, participant sense of competence, family-parent-child interactions, child competence, and program evaluation.

Findings:

1. All program participants exhibited improvements in general competence, child behavior management, anger management, and problem-solving skills.
2. Program participants exhibited moderate improvements in the use of positive and negative discipline methods and positive and negative communication strategies and in family activities.
3. In participants' ratings of their children's behavior and social competence, improvements were observed in general competence, anger management, and problem-solving skills, and orientation toward drugs, gangs, and violence was reduced.
4. Ninety-eight percent of participants reported that they would recommend the program to others. Most described the activities and components of the intervention as good or very good, and many participants who had reported noninvolvement in community activities at pretest reported involvement at posttest measurement.

###### Communication and Parenting Skills

The Communication and Parenting Skills (CAPS) program was a nine-session skills-oriented course designed to teach parental modeling of positive attitudes and behaviors and effective communication (Klein & Swisher, 1983). The program included class discussions, assigned reading, skills training, modeling of desired responses, homework, reinforcement, and values clarification. The quasi-experimental, posttest-only design included an intervention group and a waiting-list comparison group, to which assignments were made by availability. Posttest measures focused on parental sensitivity to and acceptance of children and family environment. Data were collected only once, after the intervention group completed the program and before the comparison group received the program.

Findings:

1. Participants in the intervention group expressed constructive responses to their children more often than did parents in the comparison group.
2. Participants in the intervention group expressed destructive responses less often than did those in the comparison group.
3. Parents in the intervention group reported increased respect for their children as individuals than did parents in the comparison group.

##### Parent Training With Separate Child Training

###### Creating Lasting Impressions

The Creating Lasting Impressions program of the Council on Prevention and Education: Substances involved the engagement of church communities in rural, suburban, and urban settings. The program empowered these communities to identify, recruit, and retain 12- to 14-year-old youth at high risk and their parents or guardians for participation in prevention activities. The client-level component involved a 20- to 25-week curriculum of training in substance abuse issues, family management and enhancement, communication skills for parents and youth, and substance abuse issues for youth. It included 1 year of early intervention, referral, and followup services for both parents and youth. The program highlighted wellness, health promotion, and resiliency factors.

Church community engagement findings:

- Church advocate teams were frequently, but not always, able to recruit more than the required number of families in targeted communities and were able to increase those families' level of empowerment and participation in prevention activities.

Parent resiliency findings:

- There were short-term and sustained gains in parents' levels of substance abuse knowledge and beliefs, involvement with youths in setting rules concerning substance use, and reduction of alcohol use in the African-American church community participating in the project. There were sustained gains in parents' use of community services for family or personal problems, in actions taken, and in the perceived helpfulness of community services.

Youth resiliency findings:

1. More youth in the program group than in the comparison group used community services when problems arose.
2. Short-term and sustained (but weak) increases were seen in mother-child bonding.
3. Greater increases were seen in level of communication and bonding with fathers and siblings among youth in the program group than in the comparison group, although the increases were small.

Youth substance abuse findings:

1. Short-term and/or sustained delays were seen in the onset of substance use by youth within program families where one or more of the following occurred: Parents increased their substance abuse knowledge, increased the likelihood of punishing youth for substance use, or decreased family conflict.
2. Short-term and/or sustained decreases were seen in the frequency of alcohol use by youth within program families in which one or more other improvements such as those listed above were reported.
3. Short-term and/or sustained decreases in frequency of drug use were also seen in program families showing one or more other improvements.

##### Family Skills Training

###### Families in Focus

The Families in Focus program of the Cottage Program International is an intensive family skills training program involving in-home activities designed to build family cohesion, adaptability, and communication as a way to prevent substance abuse. Professionals and/or trained volunteers provide up to 36 hours of in-home or small-group workshops in family skills training. All families complete the initial phase of the program - establishing and charting a family profile - in nine group meetings held every 2 weeks or during in-home visits made usually once weekly for 14 weeks. After assessment, families are directed to activities in the Families in Focus manual that encourage improved family functioning in seven areas: fun, decision, pride, values, feelings, communication, and confidence. Facilitator provide information and referrals if needed and suggest program-related social events and incentives to acquaint the families with community recreation activities. In this study, pretreatment and posttreatment evaluations of 119 families focused on family environment issues, such as family cohesion and adaptability, and on individual protective factors related to family, peers, and personal behavior.

Findings:

1. At posttreatment, most respondents (67 percent) reported positive changes in their perceptions of family cohesion, whereas 31 percent perceived less family cohesion.
2. Respondents perceived positive changes in family adaptability.
3. The area in which the children showed greatest positive change was their perception of supportiveness in the home environment.

###### Families and Schools Together

The Families and Schools Together (FAST) program is a family- and school-based prevention program that emphasizes enhancement of family functioning and development of protective factors, prevention of school failure and substance abuse, and reduction in family stress. Families participate in eight weekly 1.5-hour structured activities that promote cooperation and collaboration through assembling family flags, learning songs, hosting meals, reviewing the day, and playing charades based on feelings. This is followed by 2 years of similar activities on a monthly basis. At last report, the program had been implemented in at least 22 States. The effectiveness of FAST is measured in terms of reduced child problem behaviors, increased family adaptability and cohesion, decreased social insularity, and increased parental involvement in school issues and activities. Seventy-five percent of FAST participants were boys, 85 percent of whom were between the ages of 6 and 9 years. About half were African American, and about half were White. Seventy-five percent of the families were headed by a single mother, and the families had an average of three children. Most of the families were impoverished and stressed. No formal evaluation process was incorporated in the prevention case study. However, the program's information system suggests the following findings:

1. Children of families participating in the FAST program showed improvements in classroom and home behaviors and in self-esteem.
2. Parents showed improvements in community and school involvement and reduced isolation.
3. After training, parents reported improved self-esteem and an increased ability to assist their children.
4. Parents reported increased community involvement, such as obtaining a full- or part-time job, obtaining referral to counseling and addiction treatment, and participating in community groups and community center activities.

#### Research Evidence Reviewed for Approach 1, Cluster 2

The research evidence for parent and family skills training as indicated preventive measures is organized according to the level of child and parent involvement: parent training without child involvement, parent training with separate child training, family skills training, and parent training plus family skills training.

##### Parent Training Without Child Involvement

###### Arnold et al. (1975)

Arnold et al. (1975) reanalyzed data that had been gathered during an intervention designed to train parents of low socioeconomic status in social learning techniques of child management for their predelinquent children. In this nonexperimental study with a time-series design, they examined data on 55 siblings (aged 2 to 16 years) in 27 families to determine whether the parent training later resulted in reductions in the rates of deviant behavior for the target children's siblings. Fourteen noxious behaviors, such as noncompliance, yelling, and destruction, were measured during 6 to 10 baseline evaluations, weekly evaluations during the intervention, and 6 monthly followup evaluations.

Findings:

1. At posttest, the siblings demonstrated an average reduction in deviant behavior of 36 percent from baseline level.
2. At posttest, 49 percent of the siblings showed a reduction in deviant behavior of at least 30 percent.
3. Overall, these effects were maintained throughout the 6-month followup period.

###### Dubey et al. (1983)

Dubey et al. (1983) compared the effectiveness of two parent training treatment conditions (a behavior modification group and a communications group) and a delayed-treatment control group in reducing child hyperactivity, problem severity, and daily problem occurrence. In this quasi-experimental study, parents of 44 hyperactive children (primarily boys between 6 and 10 years of age) were assigned to one of two 9-week, 2-hour treatment conditions or a 10-week waiting-list condition. Parents were assigned so that groups were matched according to the child's age and score on a hyperactivity scale. The pretreatment, posttreatment, and 9-month followup measures focused on the extent and severity of hyperactivity, problem behaviors, parental attitudes, child management, and parental expectations.

Findings:

1. Parents in the treatment groups reported greater reductions in their child's hyperactivity, global severity of problems, and daily occurrences of problems than did parents in the control group. There were no intergroup rating differences for these factors.
2. Compared with their counterparts in the communications group, parents in the behavior modification group reported more global improvement in problem behaviors, greater willingness to recommend the course to a friend with children having similar problems, a stronger belief that the course was applicable to their problems, and more willingness to remain in the program.
3. Most treatment effects were maintained throughout the 9-month followup period.

###### Anastopoulos et al. (1993)

Anastopoulos et al. (1993) evaluated changes in parent functioning resulting from parental participation in a behavioral parent training program designed for school-aged children with attention deficit hyperactivity disorder. The study subjects were 34 children and their mothers. The 25 boys and 9 girls, aged 6 to 11 years, were predominantly White and middle class. The subjects were nonrandomly assigned to either parent training or a 2-month waiting-list control group. Fathers were encouraged and mothers were required to attend all sessions. The parent training consisted of a nine-session program, included use of a treatment manual and parent counseling, and was completed by most over a 2-month period. The program included an overview of information about the disorder, general principles of behavior management, positive reinforcement skills, and positive attending and ignoring skills, with instruction in reward-oriented home token/point systems and punishment. Baseline evaluations included child behavior ratings by parents and teachers, parent self-rating, parent and child interviews, observational assessment, psychological testing, and reviews of school and medical records. For the intervention group, measures were collected within 1 week after treatment and again approximately 2 months later as a followup. The waiting-list control group measures were collected at times equivalent to posttreatment and 2 months posttreatment.

Findings:

1. Relative to the waiting-list control group, subjects who completed the nine-session program showed pretreatment gains in both child and parent functioning.
2. These gains were maintained during the 2-month followup.
3. In particular, parenting stress was reduced and parenting self-esteem was increased, changes that accompanied parent-reported improvements in the overall severity of their children's attention deficit hyperactivity disorder.

###### Patterson (1974, 1975)

Patterson (1974, 1975) examined the effectiveness of a parent training procedure designed to alter the behavior of aggressive children. This nonexperimental study made multiple evaluations of 27 families who were consecutively referred by community agencies because at least one boy in each family had exhibited extreme aggressive behavior. The age range of the boys was 5 through 13 years, with a mean of 8.7 years. Most were White. The families were observed to evaluate the deviant and prosocial behaviors of their children and parent-mediated consequences of these behaviors. Parents were required to study a text on social learning-based child management techniques and were taught to identify and track rates of deviant and prosocial behavior. Each subject received an average of 32 hours of therapist time and an average of 28 hours of classroom program time. Each family received 6 to 10 home-based evaluations, including at baseline, after parents completed reading the programmed text, after 4 and 8 weeks of training, and at termination. Followup evaluations were conducted monthly for 6 months and then bimonthly during the next 6 months (for a total of nine evaluations at months 1 through 6, 8, 10, and 12). These evaluations included observations of family interactions in the family's home and daily reports by parents on children's problem behaviors.

Findings:

1. A modest reduction was observed in targeted child deviant behavior immediately after the parents read the textbook. A further reduction was observed at the 4- and 8-week evaluations, and this effect was generally maintained over the treatment period.
2. At termination there was, on average, a 60-percent reduction from baseline levels in the parent-reported and observed behaviors that had been identified by parents during the training and for which the parents had received individualized training.
3. At termination, 74 percent of the children showed reductions of 30 percent or more from baseline in deviant behavior.
4. Both observational and parent-reported followup evaluations demonstrated that deviant behavior remained at or below termination levels throughout the 12-month followup period.

###### Webster-Stratton (1984)

In an experimental study, Webster-Stratton (1984) evaluated the effectiveness of providing mothers with child management skills to enhance their parenting and reduce their children's noncompliant behavior (e.g., refusal to follow requests, tantrums, and aggression). The mean age of the 25 boys and 10 girls was approximately 5 years. Thirty-five mothers were randomly assigned to one of two treatment groups (9 weeks of individual therapy or 9 weeks of therapist-led group therapy based on a standardized videotaped modeling program) or to a waiting-list comparison group. Following the initial treatment wave, subjects in the waiting list control group were randomly assigned to one of the treatment conditions. Measures related to changes in child problem behaviors and to parent behaviors and attitudes were obtained at three points: pretreatment, posttreatment, and 1-year followup.

Posttreatment findings:

1. Both treatment groups demonstrated less child noncompliance, fewer and less severe child behavior problems, and more child prosocial behaviors than did the waiting-list comparison group. Both treatment groups also showed improved maternal behavior and resorting to less spanking.
2. Outcomes did not differ between the two treatment groups.

One-year followup findings:

1. Child noncompliance and deviant behaviors had declined from posttreatment measures.
2. The treatment groups did not differ on any maternal or child behavior measures or on parental attitudinal measures.
3. Posttreatment maternal behavior and parental attitudinal improvements were maintained.

###### Webster-Stratton (1990a)

In a similar study, Webster-Stratton (1990a) evaluated the effectiveness of a 10-week self-help videotaped parent training program consisting of two treatment conditions, with and without therapist consultation. The program was designed to provide parents with skills to reduce the noncompliance of their children with conduct disorder, enhance maternal parenting skills, and improve parent-child communication. The mean age of the 34 boys and 9 girls studied was about 5.1 years. In this experimental study, the parents were randomly assigned either to one of two treatment conditions, individually self-administered videotaped modeling (IVM) treatment or IVM treatment plus therapist consultation (IVMC), or to a waiting-list control group. Pretreatment and 1-month posttreatment measures focused on improvement in child problem and prosocial behaviors, parent-child relationships, parent behaviors and attitudes, and parent satisfaction with treatment.

Findings:

1. Mothers in the IVM and IVMC groups reported fewer child problem behaviors, less spanking, and less parental stress than did mothers in the control group. Mothers in both treatment groups also reported higher consumer satisfaction.
2. Mothers in the IVM and IVMC groups showed more positive affect toward their children than did mothers in the control group.
3. As measured by parent self-reporting and maternal observations, the differences between the IVM and IVMC groups were not significant.
4. As measured in home visits, children in the IVM group exhibited about the same number of occurrences of deviant behaviors as children in the control group.
5. As measured in home visits, children in the IVMC group displayed fewer cases of deviant behavior than did children in the IVM or control groups.
6. As measured in home visits, mothers in the IVMC group gave more praise to their children than did control mothers and gave fewer "no-opportunity" commands than did mothers in the IVM group.

###### Webster-Stratton et al. (1988, 1989), Webster-Stratton (1990b)

In an experimental study by Webster-Stratton et al. (1988, 1989) and Webster-Stratton (1990b), three treatment methods were evaluated against a waiting-list control condition for their effectiveness for 114 children having conduct problems and for their parents. The 79 boys and 35 girls had an average age of 4.5 years. The 10 to 12 weekly treatments consisted of individually administered, videotaped modeling sessions; therapist-led group discussion and videotaped modeling; or therapist-led group discussion. Children and their parents were randomly assigned to one of these conditions. Pretreatment, posttreatment, 1-year, and 3-year followup measures focused on reduction of problem behaviors among children with conduct problems and on improvement of parents' behaviors and perceptions.

Posttreatment findings:

1. In general, and compared with the control group, all treatment groups demonstrated improvements, such as fewer child behavior problems, more child prosocial behaviors, and less spanking by parents.
2. There were few differences among treatment groups on most outcome measures, although the differences that were found consistently favored the group discussion videotaped modeling treatment.
3. Individually administered videotaped modeling was the most cost-effective treatment.

One-year followup findings:

1. All significant posttreatment improvements were maintained 1 year later.
2. Approximately two-thirds of the participants demonstrated clinically significant improvements.
3. Few differences were found among the three treatment conditions. One of these differences was that group discussion plus videotaped modeling was superior to the treatments without both components.

Three-year followup findings:

1. Parents reported overall improvements over baseline in children's behavior.
2. Only treatment that combined videotaped modeling with therapist-led group discussion yielded stable improvements.

###### Webster-Stratton (1994)

In a study using an experimental design, Webster-Stratton (1994) randomly assigned 78 families with a child diagnosed as having oppositional defiant disorder or conduct disorder to one of two family skills training conditions. Most of the identified problem children were boys, and their mean age was 5 years. All families were exposed to a 12- to 13-week basic parenting skills training program of videotaped and group discussion (GDVM) designed to model parenting skills. Thirty-eight families also received GDVM plus a broader-based, 14-session videotape and group discussion component (ADVANCE), which was designed to train parents to cope with interpersonal distress through improved communication, problem solving, and self-control skills. Baseline, post-GDVM, and post-ADVANCE evaluations focused on changes in children's problem solving, children's problem behavior, parent-child communication, parent distress, and parent perception of child adjustment.

Findings:

1. Families in both conditions experienced significant improvements at short-term follow-up.
2. Families who received the combined programs showed modestly improved outcomes, compared with families who received only GDVM. Those who received the combined programs showed significant improvements in parents' problem-solving, communication, and collaboration skills, as well as in children's problem solving.

##### Parent Training With Separate Child Training

###### Horn et al. (1991), Ialongo et al. (1993)

In a study using an experimental design, Horn et al. (1991) evaluated the effectiveness of randomly assigned high-dose methylphenidate, low-dose methylphenidate, and medication placebo provided either alone or in combination with a 12-week behavioral parent training and child cognitive-behavioral self-control instruction program. Participants in the study included 96 children with attention deficit hyperactivity disorder and their parents. Most children were White, and they ranged in age from 7 to 11 years. The pretreatment, posttreatment, and 9-month followup measures (Ialongo et al., 1993) focused on changes in child problem behavior, academic achievement, and self-concept.

Posttreatment findings:

1. Methylphenidate was effective in ameliorating the primary and many of the secondary features of attention deficit hyperactivity disorder.
2. The combination of parent training and child self-control instruction was no more effective than was high- or low-dose methylphenidate alone.

Nine-month followup findings:

Nine months after the withdrawal of methylphenidate and termination of the behavioral interventions, all treatment groups experienced erosion in pretreatment-to-posttreatment gains in teacher-rated inattention, hyperactivity, and impulsivity; direct observations of off-task behavior; and performance on laboratory measures of attention and impulsivity.

###### Tremblay et al. (1991, 1995)

Tremblay et al. (1991, 1995) evaluated the effects of parent and child training on the antisocial behavior of boys identified as being disruptive in kindergarten. In this experimental-design study, 172 boys were randomly assigned either to an intervention group or to one of two nonintervention groups (an observation group or a control group). The study was designed to evaluate the effectiveness of parent and child training on the reduction of disruptive behavior, notably child antisocial behavior. The parent training included provision of a reading program, monitoring of children's behavior, giving of positive reinforcement for prosocial behavior, instruction in nonabusive punishment, management of family crises, and helping of parents to generalize what they learned. For boys, the focus was on teaching social skills, the use of fantasy, and the critical use of television. The education strategies were conducted every other week over a 2-year period, with a maximum number of 46 sessions (the mean number of sessions over 2 years was 17). The target subjects were White, French-speaking Canadian boys from low socioeconomic backgrounds and considered to be disruptive in kindergarten. Evaluations were made from the boys' teachers, peers, and mothers at baseline and at years 1, 2, 3, and 6. At the final evaluation, the boys were typically 15 years of age. Parents and teachers completed a social behavior questionnaire, which included four scales: disruptive, anxious, inattentive, and prosocial. Peer assessments were of disruptive behavior, social withdrawal, and likableness. Self-reports included questions about fighting and stealing both inside and outside the home. The observation and control groups were combined for analysis when no differences were found between them.

Findings:

1. Three years after the intervention, fewer treated boys (23 percent) than untreated boys (43 percent) were in special classes or being held back. A larger proportion of the treated than of the untreated boys were in an age-appropriate regular classroom during the elementary school years, but this difference disappeared from age 13 onward.
2. At 3 and 6 years postintervention, analysis of the self-reports revealed that treated boys were less likely than untreated boys to report fighting outside the home or stealing at home.
3. At the end of the intervention, more mothers of boys who received the intervention than of those who did not receive it assessed them as being disruptive and inattentive. However, these differentiating perceptions faded over the course of the followup.

###### Dishion and Andrews (1995)

Using a quasi-experimental study design, Dishion and Andrews (1995) evaluated the effectiveness of various components of the Adolescent Transitions Program (ATP). This program was intended to provide a supportive, nonstigmatizing, preventive intervention for high-risk families in order to promote adaptation in the adolescent years, essentially by reducing maladaptive processes. A total of 119 families was randomly assigned to receive the parent-focused component, the teen-focused component, the parent- and teen-focused components together, or a self-directed change condition with materials only. An additional 39 families were recruited as quasi-experimental control subjects who received no intervention. Families in the study were primarily White and had adolescents with at least 4 of 10 areas of early adolescent risk. The parent-focused curriculum targeted parent-family management practices and communication skills. The teen-focused intervention targeted self-regulation and prosocial behavior within the context of parent and peer environments. Other components of ATP included peer consultants for both the parent- and the teen-focused components and family therapy sessions at three strategic points in the intervention process. Families received the intervention weekly for 12 weeks. The authors examined family interaction patterns and family conflict, youth behavior problems, and adolescent tobacco use at baseline, postintervention, and 1 year after the intervention.

Findings:

1. The parent- and teen-focused interventions resulted in immediate reductions in reported and observed family conflict.
2. At 1-year followup, however, the youth who had been assigned to only the teen-focused intervention experienced an increase in behavior problems compared with control youths.
3. The parent-focused intervention resulted in immediate improvements in adolescent behavior problems at school.
4. At 1-year followup, adolescents whose parents received the parent-focused intervention had reduced their use of tobacco.

##### Family Skills Training

###### Bank et al. (1991)

Bank et al. (1991) compared the effectiveness of a parent training intervention with services traditionally provided by the juvenile court and the community. In this experimental-design study, 55 families with boys (average age 14 years) who exhibited chronic delinquent behavior were randomly assigned to the treatment condition, which averaged 45 hours of professional contact, or to the control (traditional) condition, which averaged more than 50 hours of contact. Baseline, posttreatment, and 1-, 2-, and 3-year followup evaluations focused on problem behaviors of children, behaviors of family members, juvenile justice delinquency, and days spent incarcerated.

Findings:

1. During treatment, the rate of offenses declined for both groups, but the decline was greater for the subjects receiving treatment than for control subjects.
2. Both groups experienced an overall drop in offense rates after the onset of treatment; by the end of the followup period, both groups experienced similar decreases.
3. Treatment subjects spent a total of 1,287 fewer days in institutional confinement than did their control counterparts from beginning treatment through followup.
4. Parents reported reduced delinquent behavior among children in the treatment group.

###### Baum and Forehand (1981)

Baum and Forehand (1981) examined the long-term maintenance effect of a parent training program on mother-child interactions, parents' perceptions of child adjustment, and parent satisfaction. All children were noncompliant with parental requests, and many were aggressive, destructive, and exhibited negative verbal behavior. In this one-group, nonexperimental-design study, 44 parent-child pairs completed the original program, 36 were contacted at least 1 year after treatment, 34 completed questionnaires, and 20 were the subject of in-home observations. Children's ages at followup ranged from 4 to 13 years. Baseline, posttreatment, and followup evaluations, which were performed at least 1 year after treatment, focused on mother-child interactions, parents' attitudes, children's problem behaviors, and consumer satisfaction. Treatment length was not specified in the published report.

Findings:

1. Improvements in child behavior observed at posttreatment were maintained for up to 4.5 years.
2. The improvements in parents' perceptions of child adjustment that were observed immediately after treatment were maintained at followup.
3. Parents expressed high levels of satisfaction with several aspects of the treatment program, including favorable responses to the therapist and general satisfaction with the skills taught during treatment.

###### Forehand and Long (1988) and Long et al. (1994)

Forehand and Long (1988) and Long et al. (1994) conducted two followup evaluations of subjects who had participated in a series of parent training programs several years earlier (McMahon & Forehand, 1984). Both studies employed matched community comparison groups. The initial presenting problem for the target children was noncompliance with parental requests; secondary problems included aggression, property destruction, and negative verbal behavior. Children's ages at the time of participation ranged from 2 years, 4 months to 7 years, 10 months. In most cases, only the mother and child participated in the program. The intervention consisted of 8 to 10 clinic sessions in which the parent was taught to attend to and reward appropriate behavior and to ignore minor inappropriate behavior, to issue commands and to reinforce compliance, and to use time out for noncompliance. The intervention used didactic instruction, modeling, role play, and practicing of skills both in the clinic and at home.

The first followup study was conducted 4.5 to 10.5 years after the parent training (Forehand & Long, 1988). Of the 43 parents who had participated in the parent training program at least 4.5 years earlier and whose child was now between 11 and 14 years of age, 21 agreed to participate in the followup study. A nonclinical comparison group consisted of 21 families who had not participated in parent training and whose child had never been in any type of therapy. Followup evaluations focused on problem behavior of children, parent-child disagreements, family communication and conflict behavior, children's self-perceived competence, parents' perceptions of child competence, parents' self-perceived competence, children's academic grades, child and adult depression, global marital adjustment, parental conflict, and observational ratings. Long et al. (1994) conducted another followup study of 26 late adolescents and young adults approximately 14 years after their participation in a series of parent training studies. Evaluations focused on relationships with parents, delinquency, emotional adjustment, and academic performance.

Findings at medium-term followup:

1. Overall, the functioning of families who participated in parent training because of noncompliant children was similar to that of a nonclinical comparison sample of families.
2. Few significant differences were noted among groups with regard to adolescent externalizing problems, such as conflict behavior, problem behavior, and parent-child disagreements.
3. Few significant differences were noted among groups with regard to internalizing problems, such as anxiety and withdrawal, perceived and actual competence, and behavioral observations of problem solving.
4. No differences were noted among groups with regard to parenting skills and personal adjustment.

Findings at long-term followup:

- Generally, no differences were noted in functioning across multiple areas, including delinquency, emotional adjustment, academic performance, and relationship with parents.

###### McMahon et al. (1981)

McMahon et al. (1981) examined the efficacy of incorporating formal training in social learning principles into a behavioral parent training program for mothers of children referred for the treatment of noncompliance and other oppositional behaviors. The average age of the children was slightly more than 5 years. In this quasi-experimental-design study, 20 mothers were assigned either to parent training alone or to parent training plus social learning principles training. They participated in weekly treatment sessions with the child for 5 to 6 weeks. Baseline, posttreatment, and 2-month followup evaluations focused on home observations of child-parent interactions, parents' perceptions of children's behavior, and consumer satisfaction.

Findings:

- At posttreatment, the group receiving instruction in social learning principles tended to perceive their children as better adjusted and tended to be more satisfied with treatment than did the comparison group. At followup, compared with the comparison group, children displayed an increase in child compliance. In addition, the mothers in the treatment group did the following:

1. Scored higher on their understanding of social learning principles.
2. Perceived their children as better adjusted.
3. Gave their children more attention and rewards.
4. Exhibited an increase in contingent parental attention.

###### Rogers et al. (1981)

Rogers et al. (1981) examined whether parents of low, middle, and upper socioeconomic status differed in their interactions with and perceptions of their children and in their responsiveness to parent training. The mothers in the 31 mother-child pairs that were referred by a clinic for the children's noncompliant behavior were categorized in one of the three levels and taught to use social reinforcement and time-out techniques. The mean age of the children was approximately 5 years. The frequency and duration of treatment were not described. This nonexperimental-design study employed four pretreatment and four posttreatment observations that focused on parent-child interactions and parents' attitudes toward their children.

Findings:

1. At posttreatment, no differences were noted in parental perceptions and behavior by socioeconomic status.
2. No differences in treatment response were noted among the three groups.
3. All parent groups experienced significant improvements in parent-child interactions and parental perceptions of their children.

###### Fleischman (1981)

Fleischman (1981) conducted a replication of Patterson's 1974 study evaluating parent-mediated treatment of boys with conduct problems. This nonexperimental study was designed to assess changes in child aversive behavior and parental perceptions of child behavior in 35 families with sons and daughters aged 3 to 12 years. The intervention included a formal 6-week training period for parents and an open-ended treatment period (averaging 15 weeks) with a therapist who was available by parental request. Evaluations focusing on children's and parents' positive and negative behaviors, children's aggressive acts, and parents' attitudes were conducted at baseline, during treatment, at termination, and during quarterly followups for 1 year.

Findings:

1. Significant reductions in total aversive behavior from baseline measures to termination were found for all families.
2. The degree of reduction in the target child's observed aversive behavior was greater for those families who completed treatment than for those who did not.
3. Significant changes occurred in mothers' perceptions of their targeted child; in particular, mothers perceived reduced aggression and fewer conduct problems from baseline to termination.
4. Treatment appeared to have heightened effectiveness in families with low socioeconomic status.

###### Kazdin et al. (1992)

Kazdin et al. (1992) assessed the effects of parent management training (PMT) and cognitive-behavioral problem-solving skills training (PSST) on children referred to a psychiatric facility for severe antisocial behavior. The mean age of subjects was 10 years. Four-fifths were boys, most were White, and most had a biologic mother as the primary caregiver. In this experimental-design study, children and their parents were randomly assigned to one of three treatment groups: PMT only, provided to parents; PSST only, provided to children; and PMT plus PSST, provided to parents and their children. The parents in the PMT group participated in 16 individual sessions lasting 1.5 to 2 hours each for 6 to 8 months; the children in the PSST group participated in 25 individual sessions lasting 50 minutes each for 6 to 8 months. Baseline, posttreatment, and 1-year followup evaluations focused on child behavior, child's social competence, and parent and family functioning.

Findings:

1. PMT alone, PSST alone, and PMT plus PSST combined were all associated with decreases in child dysfunction and aggressive, antisocial, and delinquent behavior and increased prosocial competence.
2. Posttreatment improvements at home, at school, and in the community were still present at 1-year followup in all but the PMT group.
3. The PMT plus PSST group experienced greater reductions than either the PMT-only or the PSST-only group in child aggression, antisocial behavior, and delinquency, as well as in parent stress, depression, and other symptoms of dysfunction.
4. More children in the PMT plus PSST group than children in the PSST-only group children whose parents were in the PMT-only group scored within the normative range of functioning after treatment and at followup.

###### Szapocznik, Rio, et al. (1986)

Szapocznik, Rio, et al. (1986) compared the effectiveness of bicultural effectiveness training (BET) and structural family therapy (SFT) in improving measures of family interactional patterns, family levels of acculturation and biculturalism, and adolescent behavior problems and psychopathology. BET uses cultural content as a basis for changing the family's style of relating to one another. In contrast, SFT focuses on changing the family's style of relating in a more process-oriented manner and may use any content that emerges from the family. This experimental-design study observed 31 Cuban-American families who had immigrated to the United States within the past 20 years and who had an adolescent manifesting symptoms of conduct disorder and/or social maladjustment. The families were randomly assigned to one of the two treatment conditions. Baseline and posttreatment measures focused on psychiatric status, child behavioral problems, structural family systems ratings, behavioral acculturation, and bicultural involvement.

Findings:

1. Families in both treatment conditions experienced improvements in family structure. No between-group differences were found.
2. Both conditions were equally effective in reducing maternal reports of adolescent behavior problems.
3. Both conditions were associated with reductions in adolescent psychopathology.
4. The biculturalism scores of participants increased more in the BET group than in the SFT group.

###### Szapocznik, Santisteban, et al. (1989)

Szapocznik, Santisteban, et al. (1989) compared the effectiveness of a minimum-contact control condition with family effectiveness training (FET), which targets maladaptive family interactions and intergenerational and intercultural conflicts. The FET program offered a series of 13 weekly sessions lasting 1.5 to 2 hours each. In this experimental-design study, 79 Hispanic families (76 percent Cuban and 24 percent other Hispanic) with preadolescents at risk for substance abuse were randomly assigned to one of two intervention groups or to one of two control groups. Seventy-one percent of the children were boys. The complicated research design (Solomon four-group design) included one baseline, one posttreatment, and two followup assessments (at weeks 13 and 39). Measurements focused on child behavior problems, children's self-concepts, structural family system ratings, and family environment.

Findings:

1. Parents of children in the FET group reported fewer behavior, personality, and inadequacy problems at treatment termination than did their counterparts in the control groups.
2. Children in the FET group reported greater improvements in their feelings about themselves than did children in the control groups.
3. Families in the FET group were generally observed to have greater improvements in family structure and organization, resonance (responsiveness of family members to each other), and development (appropriateness of behavior to role and age) than did families in the control groups.

###### Santisteban et al. (1996)

A study by Santisteban et al. (1996) examined the effectiveness of engagement family therapy, which combines brief strategic family therapy with strategic structural systems engagement as a method of bringing into and engaging in treatment families described as "difficult to reach." The study was also designed to examine factors associated with differential effectiveness. The study subjects were 193 Hispanic families of adolescents suspected of or at risk for substance abuse. The families had telephoned a family guidance center seeking services. Seventy percent of the adolescents were boys, aged 12 to 18. Approximately half of the subjects were Cuban Hispanics; the other half were composed of non-Cuban Hispanic families from Nicaragua, Colombia, Puerto Rico, Peru, Mexico, and El Salvador. The families were randomly assigned to the intervention condition or to one of two control conditions: brief strategic family therapy without engagement family therapy, or group therapy without engagement family therapy. Evaluations focusing on engagement and maintenance in therapy were conducted at intake and at an in-office therapy session within 4 weeks of initial contact.

Findings:

1. Eighty-one percent of the families assigned to the intervention condition and 60 percent in the control condition were successfully engaged in treatment.
2. Nearly all (97 percent) of the non-Cuban Hispanics and more than half (64 percent) of the Cuban Hispanics were successfully engaged in treatment.
3. An analysis of intervention failures suggests that culture and ethnicity were significant moderators of effectiveness in the intervention condition. The intervention was effective across the board, with the specific exception of Cuban families, who demonstrated parental resistance. Among these families, there appeared to be resistance of a type that was not effectively addressed by the intervention.

##### Parent Training Plus Family Skills Training

###### Bernal et al. (1980)

In a quasi-experimental-design study, Bernal et al. (1980) compared the effectiveness of two treatment approaches, behavioral parent training and client-centered parent counseling, in reducing problem behaviors among children with conduct disorder. Most of the 36 children studied were boys and ranged in age from 5 to 12 years. Their families were randomly assigned to one of two 8-week, 10-session treatment conditions until the therapists' and supervisors' client caseloads were full. Thereafter, families were randomly assigned to one of the two treatment conditions or to a waiting-list control group. The 5-week baseline and posttreatment evaluations focused on changes in child problem behaviors and in parent behaviors and perceptions.

Findings:

1. Parent reports and tests of child deviance and parent satisfaction showed a superior outcome for the behavioral group over the client-centered and waiting-list control groups, with no differences between the latter two groups.
2. At followup, however, the superior outcomes were not maintained.
3. Home observation data did not show an advantage of behavioral over client-centered treatment, nor did these two groups improve significantly in comparison with the waiting-list control group.

###### Dumas (1984)

Dumas (1984) evaluated the effectiveness of a behavioral parent training program designed to teach parents to respond appropriately to and modify the aggressive and oppositional behavior of their children (aged 2 to 11 years). This one-group, nonexperimental-design study included a pretest, a posttest, and a 1-year followup evaluation and examination of the differences between mothers who were and were not successful in the program. Training for 52 mother-child dyads was provided during weekly therapist consultations for 7 weeks. Evaluations during a 4- to 6-week baseline phase and a 1-year followup phase focused on changes in aggressive and oppositional child behavior.

Findings:

1. Unsuccessful mothers were twice as aversive toward their children as were successful mothers, and they were more indiscriminate in their use of aversive behavior.
2. Unsuccessful children were more aversive than were successful children during treatment and at followup.
3. During treatment, successful mothers increased their aversive behavior only in response to their children's aversive behavior. Unsuccessful mothers increased their aversive behavior independently of their children's behavior.
4. Most of the unsuccessful dyads scored high on several measures of socioeconomic disadvantage.

###### Hughes and Wilson (1988)

To evaluate the effectiveness of two 7-week parent training programs designed to modify the behavior of 42 children with conduct disorder, Hughes and Wilson (1988) conducted an experimental study with random assignment to either contingency management training or communication skills training or to a waiting-list control group. For each type of treatment, one-half of the parents in the group participated in the sessions with the child present. Pretreatment and posttreatment measures focused on changes in general child problem behaviors as measured by behavior problem checklists, daily report diaries, parent attitude surveys, and children's self-concept scales. Most of the children in the sample were boys, and their average age was 12 years. Of the 52 parents, 41 were women and 11 were men. Sixteen were single parents, 20 were from dual-parent couples in which both partners were participating in the study, and 16 were from dual-parent couples in which only one partner was participating. All parents were from a low socioeconomic area of a city.

Findings:

1. Parents who received either contingency management or communication skills training reported improvements in the behavior of their children in comparison with the control group.
2. Contingency management training was more effective than communication skills training in the proportion of children who reached at least a 30 percent reduction in problem behavior.
3. Participation of the child during the sessions did not have an impact on the effectiveness of either contingency management training or communication skills training.

###### Wahler et al. (1993)

Wahler et al. (1993) compared the impact of parent training alone and in combination with "synthesis teaching," a process in which the therapist and parent discuss the parent's child care experiences and other experiences that influence parenting. Subjects were referred to the study by social service agencies because of chronic oppositional and aggressive behavior of their children at home and in school. Of the children in the sample, 79 percent were boys, and 83 percent were White. The average age of the children was 7.5 years. Over one-third of the mothers were single parents with low incomes. All mothers described themselves as isolated and frequently harassed. The purpose of the experimental-design study was to identify differences in the experiences of these two sets of women. A total of 29 mother-child dyads were randomly assigned to one of the two treatment conditions and received 60- to 90-minute weekly clinic sessions for 9 months. At baseline and at 6 and 12 months, the investigators measured children's aversive responses and assessed maternal inconsistency during child-mother responses and a coding of conversations between mothers and therapists.

Findings:

1. No evidence of a treatment effect was found during the treatment period.
2. At the 6-month followup, mothers who received the combined treatment showed significantly fewer indiscriminate reactions than did the mothers receiving only parent training.
3. At the 12-month followup, children of mothers who received the combined treatment showed fewer incidents of aversive behavior than did children of mothers who received parent training only. These children also became less aversive in their behavior over the measurement phases.

#### Practice Evidence Reviewed for Approach 1, Cluster 2

The practice evidence for parent and family skills training as indicated preventive measures addresses family skills training.

##### Family Skills Training

###### Nurturing Program for Parents and Children

The Nurturing Program for Parents and Children was designed to modify abusive or potentially abusive parent-child interactions by providing training on developmental expectations, empathy, behavior management, and self-awareness. A nonexperimental-design evaluation was conducted with 121 abusive adults and their 150 abused children who participated in more than 15 sessions lasting 2.5 hours each. Subjects were primarily White, poor, and from Midwestern cities. Sixty percent were unemployed. Baseline, posttest, and 1-year followup measures focused on parent-child interactions, parents' knowledge of behavior management, parenting attitudes of parents and children, personality characteristics of parents and children, and rates of parental child abuse.

Findings:

1. Positive changes occurred in the parenting and child-rearing attitudes of abusing parents.
2. At 1-year posttreatment, parents maintained empathic attitudes toward children's needs and a clear differentiation of parent-child roles. Attitude changes regarding corporal punishment and inappropriate developmental expectations were not generally maintained.
3. Positive changes occurred among both parents and children regarding child self-awareness and parent-child role reversal.
4. At 1-year posttreatment, children continued to increase their self-awareness and to decrease their beliefs in the value of corporal punishment.
5. Positive personality changes among parents included intelligence, enthusiasm, social boldness, and self-assuredness, as well as decreases in radicalism, anxiety, and tough poise.
6. Positive personality changes among children included increases in assertiveness, enthusiasm, and tough poise.
7. At posttreatment, positive changes in family patterns included increases in family cohesion, expressiveness, independence, and a decrease in family conflict.
8. One-year posttreatment, further positive family changes included increases in family cohesion, expressiveness, organization, a moral-religious emphasis, and decreases in family conflict.
9. At 1-year followup, 7 percent of the families had been charged with additional acts of child abuse.

##### Collateral Evidence Reviewed for Approach 1

The following research evidence for Approach 1 focuses on parent training combined with teacher training. Because the parent and teacher training occurred concurrently, it is not possible to determine the effects of the parent training only. As a result, the following collateral evidence was not used in the assessment of the level of evidence for Prevention Approach 1. However, it is presented here because this research may shed light on the issues under discussion.

###### Hawkins, Von Cleve, and Catalano (1991)

Hawkins, Von Cleve, and Catalano (1991) evaluated the short-term effectiveness of concurrent parent and teacher training programs against antisocial behavior in 1st and 2nd grade students. A total of 458 children were evaluated, and 37 teachers participated in the study. Approximately half the students were non-White boys. Parents of students randomly assigned to the treatment condition were offered parent training involving modeling of skills, role playing, feedback, and homework. The parent training program was offered in seven consecutive weekly sessions to all parents of students in the intervention group when their children were in the 1st grade and again when they were in the 2nd grade. First grade teachers received training in proactive classroom management methods, interactive teaching, and cognitive social skills prior to the program. Second grade teachers received the same training prior to the subjects' entry in the 2nd grade. In this experimental longitudinal study, a self-report inventory measuring prosocial and antisocial orientations was completed by 1st grade students at the start of the school year. A teacher report was used to measure the program's effect at the end of the 2nd grade. Program implementation was based on a weekly teacher report and on observations in the fall and spring when subjects were in the 2nd grade.

Findings:

1. Boys in the intervention group were rated lower (i.e., better) on a child behavior checklist on the aggressive and externalizing antisocial subscales than boys in the control group.
2. African-American boys in both groups had similar levels of aggressive and externalized deviant behavior, suggesting that the intervention did not have an effect on them.
3. White boys in the intervention group were less aggressive and had less externalized deviant behavior after the intervention than did White boys in the control group.
4. Girls in the intervention group were rated lower (i.e., better) on the self-destructiveness subscale than were girls in the control group.
5. White girls in the intervention group were rated as less self-destructive, depressed, and nervous-anxious after the intervention than were White girls in the control group.
6. Ratings of African-American girls in both groups did not differ on any scale. The reason for different effects of the intervention between African-American and White children is not known, but this indicates a need for studies of intervention effects according to ethnic backgrounds and gender.

###### Hawkins et al. (1992)

In a modified followup to the Hawkins et al. (1991) study described above, Hawkins et al. (1992) further assessed the impact of the parent and teacher training program on child attachment and commitment to school and the initiation of alcohol use at an early age. The followup study expanded the sample to include children in grades 1 through 4 in the original schools and 5th grade students at an additional 12 schools in the Seattle school system when the original sample reached the 5th grade. This followup study examined the impact of the interventions on children in the 5th grade on the following measures: child perception of proactive family management by parents, family communication, family bonding, attachment and commitment to school, rates of initiation of delinquent behavior, and rates of alcohol use initiation. Nearly half of the sample participants were White, 25 percent were African American, and 21 percent were Asian American.

Findings:

- Students who received the intervention were significantly more likely than those who did not to report the following:

1. Proactive family management by their parents.
2. Greater family communication and involvement.
3. Greater bonding with family.
4. Perception of school as more rewarding.
5. More attachment and commitment to school.
6. Not having ever had an alcoholic drink.
7. Not having begun delinquent behavior.

### Abstracts for Prevention Approach 2: Family In-Home Support as Indicated Preventive Measures

#### Research Evidence Reviewed for Approach 2: Family In-Home Support

The following abstracts of research studies constitute the research evidence for family in-home support as indicated preventive measures.

##### Henggeler et al. (1992)

Henggeler et al. (1992) evaluated the effectiveness of multisystemic therapy (MST), a family- and home-based treatment. MST is designed to intervene directly in systems and processes such as parental discipline, family affective relations, peer associations, and school performance, which are known to be related to antisocial behavior in adolescents. In this experimental design study, 84 youth and their families were randomly assigned to either MST or the standard services provided by the Department of Youth Services. Youth in the control group received court orders including one or more stipulations, such as curfew and school attendance requirements. The 43 youth and their families who received MST participated in the intervention for an average of 13 weeks, averaging 33 hours of direct contact with therapists. The 41 youth in the control group met at least monthly with probation officers, who emphasized the importance of complying with the stipulations and the consequences of not doing so. Baseline and posttreatment measures focused on socioeconomic characteristics, justice system and criminal involvement, and psychosocial characteristics. A followup study was conducted by Henggeler et al. (1993) an average of 2.4 years after participants' referral to the original study, focusing on socioeconomic status and social characteristics, as well as justice system involvement and criminal activity.

Findings:

1. At posttreatment, subjects in the MST group had fewer arrests and less incarceration and self-reported criminal activity than did those in the control group.
2. At posttreatment, families in the MST group showed more improvement in outcomes related to family cohesion and aggression with peers than those in the control group.
3. At posttreatment, MST was shown to be equally effective for youths and families with varying cultural backgrounds and psychosocial strengths and weaknesses and for youths of both sexes.
4. At 120 weeks after referral to the original study, 39 percent of subjects in the MST group and 20 percent of those in the control group had not been rearrested.
5. The mean times to rearrest for youths receiving MST and for youths in the control group were 56 and 32 weeks, respectively.

##### Borduin et al. (1995)

Borduin et al. (1995) replicated the above studies of Henggeler et al. (1992, 1993) examining use of MST with juvenile serious offenders. This study added several important methodological improvements, including a relatively large sample size to permit subgroup analyses, a longer followup period for rearrests, observational measures of family relations, and a comparison group that received roughly the equivalent number of treatment hours. The experimental-design study, using pretest and posttest measures, a control group, random assignment to conditions, and a 4-year followup evaluation for arrests, was used to compare the effectiveness of MST with that of individual therapy. The study sample consisted of 176 families, each of which had an adolescent offender aged 12 to 17 years who was referred by juvenile court personnel. The youths had an average of 4.2 previous arrests, and the mean severity of the most recent arrest was 8.8 on a 17-point seriousness scale, where 8 corresponds to assault and battery. The group was 68 percent boys, 70 percent White, and 30 percent African American. The average numbers of treatment hours were 24 for MST and 29 for individual therapy. Evaluations, which focused on individual adjustment, family relations, peer relations, and criminal activity, were conducted at baseline, postintervention, and 4 years later.

Findings:

1. At posttest, MST was more effective than individual therapy in improving key family correlates of antisocial behavior and in ameliorating adjustment problems in individual family members. There were improvements in perceived family relations and observed family interactions, decreased symptomatology in parents, and decreased behavior problems in the youths.
2. Analysis of the 4-year followup rearrest data showed that MST was more effective than individual therapy in preventing criminal behavior, including violent offenses. The offenses were less serious for youths treated with MST who had been rearrested than for their untreated peers.

##### Walton et al. (1993)

Walton et al. (1993) compared the effectiveness of an in-home, family-based reunification service with routine out-of-home care reunification services in returning children to and keeping them in their homes. The sample of children was primarily White and ranged in age from 1 to 17 years, with a mean age of 11 years. Most caregivers were White women with low incomes. Intensive in-home reunification services were provided by caseworkers over a 90-day period, with at least three weekly home visits per family. The services provided included transportation, cash assistance, clothing, basic food items, household repairs, and training in such skills as communication, parenting, and anger management. Caseworkers assigned to the control group visited the child monthly to ensure stable placement and to assist the family in obtaining the resources necessary to enable the child to return home (e.g., mental health counseling and parenting skills training). In this experimental-design study, 110 families were randomly assigned to the treatment or the control condition. Evaluations were conducted at baseline, at the end of the 90-day service period, and at 6 and 12 months after the end of the service period. Evaluations focused on general placement issues and demographic characteristics.

Findings:

1. More children in the intervention group than in the control group (93 percent versus 29 percent) had been returned to their homes at the end of the 90-day intervention period, at the 6-month followup (70 percent versus 41 percent), and at 12 months after the intervention period (75 percent versus 49 percent).
2. Children in the intervention group spent a greater average number of days than did control children living at home during the 90-day intervention period (65 versus 15 days), during the first 6-month followup period (141 versus 83 days), and during the second 6-month followup period (151 versus 83 days).
3. During the total 15-month intervention and followup, more children in the intervention than in the control group returned to and remained at home or, after returning home, reentered out-of-home care briefly and then returned (77 percent) than did children in the control group (47 percent).

##### Lutzker et al. (1984)

Lutzker et al. (1984) compared the effectiveness of conventional child protection services with that of Project 12-Ways, an in-home ecobehavioral approach to the treatment and prevention of child abuse and neglect. Project 12-Ways is a comprehensive, multiple-setting behavior management program that provides services directly in clients' homes, schools, foster care settings, and day-care settings. Services include training in parent-child skills, basic life skills, health maintenance and nutrition, home safety, stress reduction, money management, leisure time, job finding, and self-control. Other available services include alcoholism treatment referral and marital counseling. This nonexperimental study used a historical cohort design, reconstructing data from records for a group receiving services from Project 12-Ways and for a comparison group. Evaluation was limited to the family abuse recidivism rate, based on State reports of child abuse and neglect. The quantity and duration of services were not described for either condition. In a supplemental study, Lutzker and Rice (1987) examined data on repeat child abuse and neglect for 710 families from 1 to 5 years after receiving Project 12-Ways services.

Findings:

1. The abuse recidivism rates were consistently lower for families in the treatment group than for those in the comparison group, but over time the rate increased for both groups.
2. For fiscal year 1980, recidivism rates were 4 percent for families in the treatment group and 26 percent for those in the comparison group.
3. For fiscal year 1981, recidivism rates were 12 percent for families in the treatment group and 28 percent for those in the comparison group.
4. For fiscal year 1982, recidivism rates were 22 percent for families in the treatment group and 31 percent for those in the comparison group.
5. For fiscal year 1983, recidivism rates were 25 percent for families in the treatment group and 35 percent for those in the comparison group.

Findings from the supplemental study:

1. Families receiving Project 12-Ways services were less likely to engage in child abuse than were families receiving other child protection services (21 percent versus 29 percent).
2. For all treatment years except fiscal year 1981, families who received Project 12-Ways services had lower recidivism rates than did families who received other child protection services.
3. The cumulative recidivism rate increased gradually for both treatment groups.

##### Berry (1992)

Berry (1992) evaluated the effectiveness of intensive family preservation services provided by the In-Home Family Care program in preventing the out-of-home placement of children. An additional goal of this study was to identify family and service characteristics associated with successful family preservation. This nonexperimental study examined data from a historical cohort over a period of 3 years. The study sample included 411 families, including 896 children, in San Francisco and Oakland, California, most of whom were African American, Latino, or White. All families had at least one child at risk of imminent out-of-home placement. Measurements were derived from demographics, child and parent problems, family function level, household resource level, family cooperation levels, service characteristics, and placement within 6 or 12 months after service termination.

Program effectiveness findings:

1. Of 367 families for whom data were available and who received intensive family preservation services, 88 percent avoided child removal for 12 months after receiving services.
2. Of the 896 children served in the 3-year study period, 96 (11 percent) were placed in out-of-home care.

Family and service characteristics:

1. Families with members having a developmental disability or mental handicap had more out-of-home placements than did families without such problems (24 percent versus 13 percent).
2. Families experiencing child placement were rated as less cooperative during the service period than were families that did not experience placement.
3. Families who remained together began treatment at higher levels of functioning than did families who experienced child placement in measures of noncrowdedness, number of household resources, physical household condition, health care and grooming, and encouragement of childhood development.
4. The key predictor of success was the proportion rather than the amount of time the worker spent in the home.

##### Haapala and Kinney (1988)

Haapala and Kinney (1988) examined the effectiveness of Homebuilder, an intensive home-based family preservation program designed to treat status-offending youths who are in danger of imminent out-of-home placement as well as their families. The youth sample was 64 percent boys, primarily White, aged 6 to 17 years. Most had never lived in foster, group, or residential placement. Each family was linked with one Homebuilder therapist, who had a caseload of two families at a time and who was available 24 hours a day, 7 days a week. Approximately 50 hours of intervention were provided to each family for approximately 1 month. In this nonexperimental, one-group, posttest-only design, data from a subsample of 64 youths from a total sample of 678 youths focused on family problems and characteristics; sociodemographic characteristics; and placement in foster, group, or psychiatric care.

Findings:

1. Family conflict was the most common family problem at the time of referral (98 percent of youths). Other problems at referral included youths' behavior (66 percent), school-related problems (30 percent), parenting issues (30 percent), and runaway youths (25 percent).
2. Of the 678 status-offending clients receiving services, 592 (87 percent) avoided out-of-home placement during the 12-month followup period.
3. Rates of placement avoidance were stable across the 4 years of the contract. Eighty-six percent of the youth avoided placement during the first year, 91 percent during the second year, 86 percent during the third year, and 85 percent during the fourth year.

#### Practice Evidence Reviewed for Approach 2: Family In-Home Support

The following abstracts of prevention practice case studies constitute the practice evidence for family in-home support as indicated preventive measures.

##### In-Home Care Demonstration Projects

The In-Home Care Demonstration Projects resulted from California State Assembly Bill 1562, which provided funding for three self-care projects for latchkey children and eight in-home care projects to provide intensive short-term services to families of children at imminent risk of removal from the home. Within 1 week of referral, families received services such as individual counseling, crisis intervention, family counseling, parenting skills training, and case management. Families received an average of 60 hours of services over an average of 7 weeks, given approximately every other day for 2 to 4 hours. Followup services focused on linking families to support or counseling services, such as Parents Anonymous, Alcoholics Anonymous, Victims Anonymous, long-term therapy, addiction treatment, and brief consultations. Data were collected on 709 families, including 1,740 children, over a period of 3 years. Followup data were collected on 95 percent of these families and children. The legislation required an evaluation of the projects during the 3 years of operation. The in-home care projects were compared with traditional services for their effects on placement rates, placement incidents, average length of time per placement incident, and placement costs.

Findings:

1. No significant difference was found in placement rates between the intervention and comparison groups.
2. The number of average placement days was 73 for the intervention group and 77 for the comparison groups. Families who received intervention services used 1,500 fewer days of placement than did comparison families.
3. The costs of placement during the 8-month study period were $141,375 for intervention families and $145,388 for comparison families.
4. Families who experienced placement after receiving intensive in-home services were more likely than comparison families to have a primary caretaker with at least one reported disability, to be receiving public assistance, to have experienced previous placement of their children, to have subsequent investigations of abuse and neglect, and to score lower and make less progress on most indices of a child well-being scale at intake and at termination.
5. Children who were placed after receiving intensive in-home services were more likely than control children to have at least one reported disability, to be at risk of neglect rather than other types of maltreatment, to be younger, to have experienced one or more placements, and to be a dependent of the court.
6. Families who did not experience placement received more intensive services than families who did experience placement.

##### Intensive Family Preservation Services

The Intensive Family Preservation Services of the State of Connecticut are targeted to families whose children are at imminent risk of removal from their homes. Two evaluative efforts were conducted. The primary study of 662 families (1,000 adults and 1,775 children) whose children were at imminent risk of placement included a 1-year followup. A 2-year followup of 40 study families (20 families in which all children were placed and 20 families in which no children were placed) was conducted to provide information on an additional year of placement activity and the costs associated with the second followup year.

Findings from the primary study:

1. Families receiving family preservation services showed greater improvements at termination than did families not receiving services.
2. Families participating in family preservation had the greatest problems in parenting skills, which was also the area that showed the greatest improvement at termination of services.
3. Of the children participating in family preservation services, 82 percent were not placed out of their homes during the followup year. However, there were no differences in placement rates between families who were served and families who were referred but not served.
4. Almost 40 percent of the families experienced at least one critical incident during participation in services.
5. Twenty-six percent of the families terminated early from family preservation services.

Findings from the followup study:

1. Of the 20 families who experienced no placements in the first year, just 3 (7 children) experienced placement in the second year.
2. Nearly half of the children (21 of 46) who were placed during the first year were returned to their homes within 24 months, an improvement over the State average of 31 months.
3. Eighty-five percent of the 46 children who had never been placed were not removed from the study.

### Abstracts for Prevention Approach 3: Family Therapy as Indicated Preventive Measures

#### Research Evidence Reviewed for Approach 3: Family Therapy

The following are abstracts of research studies that constitute the research evidence for family therapy as indicated preventive measures.

##### Alexander and Parsons (1973), Klein et al. (1977)

Alexander and Parsons (1973) evaluated the effectiveness of a short-term, behaviorally oriented family intervention for families with delinquent teenagers aged 13 to 16 years in Salt Lake City, Utah. The intervention was designed to reduce maladaptive interaction patterns in families, to increase mutual positive reinforcement, and to reduce recidivism rates among the teenagers. In this experimental-design study with posttreatment measures only, 46 families were randomly assigned to the short-term, behaviorally oriented family therapy; 19 were assigned to a client-centered family group program; 11 attended a psychodynamic family counseling program sponsored by the Church of Jesus Christ of Latter-day Saints; and 10 were assigned to a no-treatment control group. The amount of treatment provided through short-term behavioral intervention and client-centered group treatment was not described. Posttreatment measures at 6- to 18-month intervals focused on family interactions and processes and delinquency recidivism rates. In addition, Klein et al. (1977) examined the effects of these treatment conditions with regard to contact with the court system by younger siblings 2.5 to 3.5 years after treatment termination for the referred child.

Findings:

1. The recidivism rate for delinquent youths from families receiving the short-term behavioral intervention was 26 percent. This rate was 47 percent for families receiving client-centered family group treatment, 50 percent for families receiving no treatment, and 73 percent for families receiving psychodynamic therapy.
2. Families receiving behaviorally oriented family treatment exhibited more equality (i.e., lower variance) in talk time, less silence, and more positive interruptions than did families receiving alternative or no treatment.
3. The length of time to first recidivistic offense after treatment did not vary among treatment and control groups.
4. Siblings in families that received short-term behaviorally oriented family therapy were less likely to be involved with the court system (20 percent) than were subjects receiving no treatment (40 percent), the group receiving client-centered therapy (59 percent), or the group receiving psychodynamic therapy (63 percent).

##### Barton et al. (1985)

Barton et al. (1985) reported on three studies that evaluated the effectiveness of functional family therapy (FFT) used by undergraduate paraprofessional therapists and foster care caseworkers in the treatment of seriously delinquent youth who had been recently released from a State criminal justice institution.

The goal of the "Paraprofessional Therapists" study was to evaluate the effectiveness of FFT when conducted by undergraduate paraprofessionals. In this study, eight undergraduate students received 16 FFT training sessions lasting 2 hours each, observed videotaped FFT sessions, participated in role playing, and spent 8 hours in modules on behavioral intervention procedures with children, behavioral contracting, and communication training. They participated in an average of 10 sessions with randomly assigned families of status offenders who had been referred to neighborhood probation units for three to six status offenses.

The goal of the "Foster Placement" study was to evaluate the effectiveness of FFT to treat foster care cases after receiving 1 week of FFT training. Two State foster care workers implemented FFT before deciding whether to place a child or children in foster care in 109 cases and compared the foster placement outcomes of these cases with those of 216 other State placement cases that did not receive FFT. They reviewed caseworker logs to compare case outcomes, using the proportion of cases placed in foster care for 72 hours before and after implementation of FFT training.

The goal of the "Hard-Core Delinquent Study" was to compare the effectiveness of FFT and alternative treatment in preventing recidivism of severe offenses by seriously delinquent youth who had recently been released from a State institution. Thirty youth received FFT and 44 youth received the alternative treatment, which consisted primarily of placement in a group home. All youth were monitored for 15 months after their release from incarceration.

Findings from the "Paraprofessional Therapists" study:

- The recidivism rate of 26 percent for families receiving FFT was comparable to the FFT recidivism rates in studies using professional therapists and was lower than the annual recidivism rate of 51 percent for the juvenile court district. The rates of defensiveness declined in a manner consistent with the decline in rates of defensiveness produced in other applications of FFT.

Findings from the "Foster Placement" study:

- The rate of foster care use for families who received training significantly decreased from 48 percent before FFT training to 11 percent after training. The rate of foster care use for the comparison group increased from 43 percent before FFT training to 49 percent after FFT training.

Findings from the "Hard-Core Delinquent" study:

- The recidivism rate after treatment was lower for the group receiving FFT training (60 percent) than for the group receiving alternative treatment (93 percent). Youths who received FFT treatment were significantly less likely to commit another offense than comparison youths and committed significantly fewer total offenses.

##### Gordon et al. (1988)

Gordon et al. (1988) compared the effectiveness of standard probation with a home-based, time-unlimited, behavioral-systems family therapy model in the treatment of juvenile offenders of low socioeconomic status (mean age, 15 years). In this quasi-experimental study, 54 offenders were nonrandomly assigned to treatment or to control conditions. The treatment group participated in an average of 16 sessions of therapy plus assessment and education. Their parents also received an unspecified amount of parent training. The group on probation met with a probation officer once or twice monthly. The primary outcome, recidivism, was measured by the number and severity of offenses during a 2.5-year followup period.

Findings:

1. The recidivism rates for the treatment and comparison groups were 11 and 67 percent, respectively.
2. The annual average recidivism rates for the treatment and comparison groups were 5 and 25 percent, respectively.
3. The significant differences in recidivism rates held true in gender-specific comparisons.

##### Szapocznik, Murray, et al. (1989)

Szapocznik, Murray, et al. (1989) compared the effectiveness of structural family therapy, psychodynamic child therapy, and a recreational control condition in the reduction of behavioral and emotional problems and in improvements in child and family functioning among Hispanic boys aged 6 to 12 years who had been diagnosed with opposition disorder, anxiety disorder, conduct disorder, or adjustment disorder. Treatment involved 12 to 24 contact hours over a 6-month period. Structural family therapy sessions of 60 to 90 minutes in length occurred weekly early in treatment and less frequently thereafter. The individual psychodynamic child therapy sessions consisted of one weekly 50-minute session with nondirective play situations. In this experimental study, 69 families were randomly assigned to one of two intervention conditions or to a control condition. Evaluations at baseline, posttreatment, and 1-year followup focused on attrition, child behavior problems, anxiety and depression ratings, psychodynamic child ratings, and structural family system ratings.

Findings:

1. Families receiving structural family therapy experienced more protection of family integrity than the other groups, especially as compared with the dramatic declines for families receiving psychodynamic child therapy.
2. Both treatment conditions were essentially equivalent in reducing child behavioral and emotional problems, according to parent and self-reports.
3. Both treatment conditions were essentially equivalent in improving psychodynamic ratings of child functioning.

##### Santisteban et al. (1997)

Santisteban et al. (1997) conducted a nonexperimental study to evaluate the effectiveness of brief structural family therapy to prevent drug use initiation among Hispanic and African-American youth. The sample included 103 Hispanic and 19 African-American boys and girls between the ages of 12 and 14 years who had been referred to treatment by their school counselors because of conduct problems or antisocial behavior with peers. This intervention uses a flexible implementation model to provide only as much therapy as is needed by a particular family. Most families receive 12 to 16 weekly family sessions over 4 to 6 months. All families receive the core components of joining, family pattern diagnosis, and restructuring. In this one-group study, the adolescents and their parents completed measures of adolescent behavior problems, family functioning, and substance use before treatment, immediately after treatment, and approximately 9 months after treatment.

Findings:

1. Both Hispanic and African-American adolescents experienced significant improvements in behavior problems after therapy.
2. Adolescents experienced significant reduction of social aggression and conduct problems.
3. Parents and adolescents reported significant improvements in family functioning over the course of the intervention.
4. Hispanic adolescents experienced strongest improvements in conduct disorder, anxiety and withdrawal, and family functioning.
5. African-American adolescents experienced improvements comparable to those of Hispanic students across all behavior dimensions, but only modest improvements in family functioning.
6. Improvements in parent-reported adolescent behavior problems predicted a reduced initiation of substance use after treatment.

##### Henggeler et al. (1986)

Henggeler et al. (1986) compared the effectiveness of multisystemic family-ecological therapy and an alternative therapy in improving family dynamics in families of juvenile offenders and the behavior problems of these juveniles. The mean age of the juveniles was 15 years, and 84 percent were male. The families, who lived in Memphis, Tennessee, were largely African American (65 percent) and had low socioeconomic status (75 percent), a mean size of 6.4 members, and in many cases an absent father (62 percent). In this quasi-experimental study with two treatment groups and a nonequivalent control group, 113 families were assigned nonrandomly to either multisystemic or alternative treatment. Forty-four well-adjusted adolescents served as developmental control subjects. Subjects received multisystemic therapy for an average of 20 hours. The average total number of hours of alternative treatment received by subjects was 24 hours over about 3 months. The alternative therapy varied according to agency but included client-centered and behavioral approaches. Baseline and posttreatment evaluations focused on child problem behaviors, parent and adolescent personality characteristics, and family interactions and relationships.

Findings:

- At posttreatment and compared with baseline, the following observations were made:

1. Adolescents in the multisystemic group condition demonstrated fewer conduct problems and anxious-withdrawn behaviors and less immaturity and association with delinquent peers than did those in the control condition.
2. The mother-adolescent, father-adolescent, and marital dyads in the multisystemic group condition demonstrated more affection and warmth than did those in the control condition.
3. Adolescents in the multisystemic condition were more involved in family interactions, as shown by an increase in family conversations, than were those in the control condition.
4. Adolescents in the alternative-therapy condition demonstrated no change on behavior and personality variables, and the father-adolescent and marital dyads in this group demonstrated deterioration in warmth and affection.
5. Adolescents in the control condition showed no change on behavior and personality variables and no change on family relations variables. Mothers in this condition, however, showed a decrease in supportive communications.

##### Mann et al. (1990)

Mann et al. (1990) evaluated the effectiveness of multisystemic therapy in the treatment of adolescent antisocial behavior by using the therapy to treat "cross-generational coalitions," in which a parent, usually the mother, forms a stable coalition with the child against the other parent in family transactions (as opposed to stable mother-father coalitions). In this quasi-experimental study with two treatment groups and a nonequivalent comparison group, 45 family triads (mother, father, and son or daughter) with adjudicated and delinquent adolescents (aged 13 to 17 years) were assigned to groups receiving multisystemic therapy or individual therapy. Most adolescent subjects were boys, 61 percent were White, and 39 percent were African American. Sixteen well-adjusted adolescents served as a control group. The multisystemic treatment involved a mean of 21 hours of family therapy and school-related consultation. The individual therapy, which focused on expressing feelings, developing insight, and providing support for behavior change, averaged 29 hours. Pretreatment and posttreatment evaluations focused on measures of observed family relationships and self-reported symptoms.

Findings:

1. Before treatment, families with delinquent children demonstrated evidence of cross-generational coalitions.
2. After treatment, fathers, mothers, and adolescents receiving multisystemic therapy showed greater decreases in their symptoms than did their counterparts receiving individual therapy.
3. Families in the multisystemic-treatment condition demonstrated many more positive changes in dyadic interaction than did those in the individual-therapy condition.
4. Mother-adolescent dyads in the multisystemic condition showed a greater decrease in their verbal activity than did mother-adolescent dyads in the individual-therapy group.
5. Father-adolescent dyads in the multisystemic condition showed a greater increase in supportiveness and a greater decrease in verbal activity and in conflict and hostility than did the individual-therapy group.
6. Individual symptomatology and family interactions improved from reassessment to postassessment in the treatment group but did not improve in the individual-therapy group.

##### Springer et al. (1992)

Springer et al. (1992) evaluated the effectiveness of an organized art and play therapy, embedded within peer group and family therapy, on the competencies and problem behaviors of children of individuals with substance abuse problems. The children's ages ranged from 4 to 11 years; 56 percent were White, and 39 percent were Hispanic. Forty percent of the families were headed by a single parent, and 27 percent received Aid to Families With Dependent Children. A total of 311 children participated in the program; of these, 42 percent actively participated throughout the 12-week program and were graduated. Initially, the peer group sessions and the family interaction group sessions were each 1.5 hours and took place weekly. By the end of the project period, six peer group and six family interaction sessions were held weekly. In this nonexperimental, single-group study design, baseline and posttreatment evaluations focused on child competencies and problem behaviors, the number of treatment sessions attended by children, referral sources, and demographic characteristics.

Findings:

1. Parent reports of child competencies increased and problem behaviors decreased for the total sample at posttreatment compared with baseline.
2. Among boys aged 6 through 11 years, significant improvements were noted in four syndromes: depression, hyperactivity, delinquency, and aggressiveness.
3. Among girls aged 6 through 11 years, significant improvements were noted in four syndromes: sexual problems, depression, cruelty, and hyperactivity.

##### McPherson et al. (1983)

An experimental-design study by McPherson et al. (1983) compared the effectiveness of short-term, intensive family counseling with casework-oriented probation for youthful offenders. The subjects were 75 offenders who had committed a status offense, misdemeanor, or felony; had not been supervised before by the county juvenile court; and were less than 17 years of age. They were randomly assigned by systematic sampling to intervention (n = 15) and control (n = 60) conditions. The intervention was family counseling, with approximately 10 sessions lasting 2 hours each for 3 to 4 months. Some sessions were held jointly with the parents and children, and other family members were encouraged to participate. The therapy was designed to help participants acquire new skills and ideas, understand and appreciate one another, improve communication, learn effective discipline methods, learn self-management skills, and examine their own and other family members' expectations.

The effectiveness of the treatment was measured by reduced recidivism (referral of any kind, criminal referrals, or stay in detention at 4 and 7 months) and improved family functioning. Recidivism was evaluated during two time periods: from the date of assignment to the end of the 4-month treatment phase, and from the date of assignment to the end of 7 months. Fifteen control-group subjects were randomly assigned to a subcontrol group to measure and compare family functioning with the 15 intervention subjects. These subjects were evaluated on four measures of family functioning at the end of 3 months after assignment: parental child-rearing attitudes, parent-adolescent communication, parent's report of the child's behavior problems, and parent's report of the child's social competence.

Findings:

1. Family counseling was more effective than probation in reducing the percentage of recidivists and the amount of recidivism for total (any kind) and criminal referrals during both time periods.
2. Family counseling was more effective than probation with regard to two family functioning measures: Parents receiving the intervention had less need to maintain excessive control over their children than control parents, and children receiving the intervention demonstrated greater social competence than control subjects.
3. Family counseling, however, was not more effective than probation in improving the quality of communication or decreasing children's behavior problems.

### Research Evidence Reviewed

Aktan, G. B., Kumpfer, K. L., & Turner, C. W. (1996).Substance Use and Misuse, 31
Alexander, J. F., & Parsons, B. V. (1973).Journal of Abnormal Psychology, 81
Anastopoulos, A. D., Shelton, T. L., DuPaul, G. J., & Guevremont, D. C. (1993).Journal of Abnormal Child Psychology, 21
Arnold, J. E., Levine, A. G., & Patterson, G. R. (1975).Journal of Consulting and Clinical Psychology, 43
Bank, L., Marlowe, H., Reid, J. B., Patterson, G. R., & Weinrott, M. R. (1991).Journal of Abnormal Child Psychology, 19
Barton, C., Alexander, J. F., Waldron, H., Turner, C. W., & Warburton, J. (1985).American Journal of Family Therapy, 13
Baum, C. G., & Forehand, R. (1981).Behavior Therapy, 12
Bernal, M. E., Klinnert, M. D., & Schultz, L. A. (1980).Journal of Applied Behavior Analysis, 13
Berry, M. (1992).Social Work, 37
Borduin, C. M., Mann, B. J., Cone, L. T., Henggeler, S. W., Fucci, B. R., Blaske, D. M., & Williams, R. A. (1995).Journal of Consulting and Clinical Psychology, 63
Catalano, R. F., Haggerty, K. P., Gainey, R. R., Hoppe, M. J., & Social Development Research Group. (1995).Reducing parental risk factors for children's substance abuse: Preliminary outcomes with opiate-addicted parents.
Dishion, T. J., & Andrews, D. W. (1995).Journal of Consulting and Clinical Psychology, 63
Dubey, D. R., O'Leary, S. G., & Kaufman, K. F. (1983).Journal of Abnormal Child Psychology, 11
Dumas, J. E. (1984).Journal of Consulting and Clinical Psychology, 52
Felner, R. D., Brand, S., Erwin Mulhall, K., Counter, B., Millman, J. B., & Fried, J. (1994).Journal of Primary Prevention, 15
Fleischman, M. J. (1981).Journal of Consulting and Clinical Psychology, 49
Forehand, R., & Long, N.Advances in Behaviour Research and Therapy, 10
Gordon, D. A., Arbuthnot, J., Gustafson, K. E., & McGreen, P. (1988).American Journal of Family Therapy, 16
Guerney, L. (1977).American Journal of Community Psychology, 5
Guerney, L. F., & Wolfgang, G. (1981).Journal of Clinical Child Psychology, 10
Haapala, D. A., & Kinney, J. M. (1988).Criminal Justice and Behavior, 15
Henggeler, S. W., Rodick, J. D., Borduin, C. M., Hanson, C. L., Watson, S. M., & Urey, J. R. (1986).Developmental Psychology, 22
Henggeler, S. W., Melton, G. B., & Smith, L. A. (1992).Journal of Consulting and Clinical Psychology, 60
Henggeler, S. W., Melton, G. B., Smith, L. A., Schoenwald, S. K., & Hanley, J. H. (1993).Journal of Child and Family Studies, 2
Horn, W. F., Ialongo, N. S., Pascoe, J. M., Greenberg, G., Packard, T., Lopez, M., Wagner, A., & Puttler, L. (1991).Journal of the American Academy of Child and Adolescent Psychiatry, 30
Hughes, R. C., & Wilson, P. H. (1988).Child and Family Behavior Therapy, 10
Ialongo, N. S., Horn, W. F., Pascoe, J. M., Greenberg, G., Packard, T., Lopez, M., Wagner, A., & Puttler, L. (1993).Journal of the American Academy of Child and Adolescent Psychiatry, 32
Kazdin, A. E., Siegel, T. C., & Bass, D. (1992).Journal of Consulting and Clinical Psychology, 60
Klein, N. C., Alexander, J. F., & Parsons, B. V. (1977).Journal of Consulting and Clinical Psychology, 45
Knapp, P. A., & Deluty, R. H. (1989).Journal of Consulting and Clinical Psychology, 18
Kosterman, R., Hawkins, J. D., Haggerty, K. P., Spoth, R., & Redmond, C. (1996).Preparing for the drug free years: Session-specific effects of a universal parent training intervention with rural families.
Kosterman, R., Hawkins, J. D., Haggerty, K. P., Spoth, R., and Redmond, C.Journal of Community Psychology, 25
Kumpfer, K. L., & DeMarsh, J. P. (1987).Prevention services for children of substance-abusing parents.
Kumpfer, K. L., Turner, C. W., & Palmer, S. (1991).YCOSA Black parenting project: Third and fourth year evaluation report.
Long, P., Forehand, R., Wierson, M., & Morgan, A. (1994).Behaviour Research and Therapy, 32
Lutzker, J. R., & Rice, J. M. (1987).Journal of Family Violence, 2
Lutzker, J. R., Wesch, D., & Rice, J. M. (1984).Advances in Behaviour Research and Therapy, 6
Mann, B. J., Borduin, C. M., Henggeler, S. W., & Blaske, D. M. (1990).Journal of Consulting and Clinical Psychology, 58
McMahon, R. J., Forehand, R., & Griest, D. L. (1981).Journal of Consulting and Clinical Psychology, 49
McPherson, S. J., McDonald, L. F., & Ryer, C. W. (1983).Juvenile & Family Court Journal, 34
Myers, H. F., Alvy, K. T., Richardson, M., Arrington, A., Marigna, M., Huff, R., Main, M., & Newcomb, M.The Effective Black Parenting program: A control research study with inner-city Black families.
Patterson, G. R. (1974).Canadian Psychiatric Association Journal, 19
Patterson, G. R. (1975).Applications of Behavior Modification
Rogers, T. R., Forehand, R., Griest, D. L., Wells, K. C., & McMahon, R. J. (1981).Journal of Clinical Child Psychology, 10
Santisteban, D. A., Coatsworth, J. D., Perez-Vidal, A., Mitrani, V., Jean-Gilles, M., & Szapocznik, J. (1997).Journal of Community Psychology, 25
Santisteban, D. A., Szapocznik, J., Perez-Vidal, A., Kurtines, W. M., Murray, E. J., & LaPerriere, A. (1996).Journal of Family Psychology, 10
Spoth, R. (in press).Prevention through family interventions
Spoth, R., & Redmond C. (1996).Family Relations, 45
Spoth, R., Redmond, C., Hockaday, C., & Yoo, S. (1997).American Journal of Community Psychology, 24
Spoth, R., Redmond, C., & Shin, C. (in press 1998).Journal of Consulting and Clinical Psychology.
Spoth, R., Redmond, C., Shin, C., & Huck, S. (in press).Journal of School Psychology.
Spoth, R., Redmond, C., Haggerty, K., & Ward, T. (1995).Journal of Marriage and the Family, 57
Spoth, R., Reyes, M. L., & Redmond, C. (1997).Assessing a public health approach to delay onset and progression of adolescent substance use: Latent transition analysis of longitudinal family preventive intervention outcomes.
Spoth, R., Yoo, S., Kahn, J. H., & Redmond C. (1996).Journal of Primary Prevention, 16
Springer, J. F., Phillips, J. L., Phillips, L., Cannady, L. P., & Kerst-Harris, E. (1992).Journal of Community Psychology,
Szapocznik, J., Murray, E., Scopetta, M., Hervis, O., Rio, A., Cohen, R., Rivas-Vazquez, A., Posada, V., & Kurtines, W. (1989).Journal of Consulting and Clinical Psychology, 57
Szapocznik, J., Rio, A., Perez-Vidal, A., Kurtines, W., Hervis, O., & Santisteban, D. (1986).Hispanic Journal of Behavioral Sciences, 8
Szapocznik, J., Santisteban, D., Rio, A., Perez-Vidal, A., Santisteban, D., & Kurtines, W. M. (1989).Hispanic Journal of Behavioral Sciences, 11
Thompson, R. W., Grow, C. R., Ruma, P. R., Daly, D. L., & Burke, R. V. (1993).Family Relations, 42
Tremblay, R. E., McCord, J., Boileau, H., Charlebois, P., Gagnon, C., Le Blanc, M., & Larivee, S. (1991).Psychiatry, 54
Tremblay, R. E., Pagani-Kurtz, L., Masse, L. C., Vitaro, F., & Pihl, R. O. (1995).Journal of Consulting and Clinical Psychology, 63
Wahler, R. G., Cartor, P. G., Fleischman, J., & Lambert, W. (1993).Journal of Abnormal Child Psychology, 21
Walton, E., Fraser, M. W., Lewis, R. E., Pecora, P. J., & Walton, W. K. (1993).Child Welfare, 72
Webster-Stratton, C. (1984).Journal of Consulting and Clinical Psychology, 52
Webster-Stratton, C. (1990a).Journal of Abnormal Child Psychology, 18
Webster-Stratton, C. (1990b).Journal of Clinical Child Psychology, 19
Webster-Stratton, C. (1994).Journal of Consulting and Clinical Psychology, 62
Webster-Stratton, C., Kolpacoff, M., & Hollinsworth, T. (1988).Journal of Consulting and Clinical Psychology, 56
Webster-Stratton, C., Kolpacoff, M., & Hollinsworth, T. (1989).Journal of Consulting and Clinical Psychology, 57
Wolchik, S. A., West, S. G., Westover, S., Sandler, I. N., Martin, A., Lustig, J., Tein, J. Y., & Fisher, J. (1993).American Journal of Community Psychology, 21

### Practice Evidence Reviewed

- The Communication and Parenting Skills program. Milwaukee, WI.
- The Creating Lasting Impressions program of the Council on Prevention and Education: Substances. Louisville, KY.
- The Families and Schools Together program of Family Service. Madison, WI.
- The Families in Focus program of Cottage Program International. Salt Lake City, UT.
- The In-Home Care Demonstration Projects of the Office of Child Abuse Prevention, Department of Social Services, State of California. Sacramento, CA.
- The Intensive Family Preservation Services of the State of Connecticut. Hartford, CT.
- The Kansas Family Initiative of the Kansas Department of Social and Rehabilitation Services. Topeka, KS.
- The Nurturing Program for Parents and Children. Eau Clair, WI.
- The Parenting for Prevention program of the King County Department of Alcohol and Substance Abuse Services. Seattle, WA.

### References

Gordon, R. (1983).Public Health Reports, 98
Gordon, R. (1987).Preventing mental disorders
Hawkins, J. D., Von Cleve, E., & Catalano, R. F. (1991).Journal of the American Academy of Child and Adolescent Psychiatry, 30
Hawkins, J. D., Catalano, R. F., Morrison, D. M., O'Donnell, J., Abbott, R. D., & Day, L. E. (1992).Preventing antisocial behavior: Interventions from birth through adolescence
Henggeler, S. W., Schoenwald, S. K., Pickerel, S. G., Rowland, M. D., & Santos, A. B. (1994).The Journal of Mental Health Administration, 21
Klein, M. A., & Swisher, J. D. (1983).Journal of Drug Education, 13
Loeber, R. (1988).Advances in Clinical Child Psychology
McMahon, R. J., & Forehand, R. (1984).Parent training: Foundations of research and practice
Nelson, K. E., Landsman, M. J., & Deutelbaum, W. (1990).Child Welfare, 69
Szapocznik, J., & Kurtines, W. M. (1980).Psychological dimensions on the acculturation process: Theory, models, and some new findings
Szapocznik, J., & Kurtines, W. M. (1993).American Psychologist, 48
Szapocznik, J., Kurtines, W. M., & Fernandez, T. (1980).International Journal of Intercultural Relations, 4
Szapocznik, J., Kurtines, W. M., Santisteban, D. A., Pantin, H., Scopetta, M., Mancilla, Y., Ainsenberg, A., McIntosh, S., Perez-Vidal, A., & Coatsworth, J. D. (1996).Handbook of Latino psychology.
Szapocznik, J., Rio, A., Perez-Vidal, A., Kurtines, W., Hervis, O., & Santisteban, D. (1986).Hispanic Journal of Behavioral Sciences, 8
Szapocznik, J., Santisteban, D., Kurtines, W. M., Perez-Vidal, A., & Hervis, O. E. (1984).Hispanic Journal of Behavioral Sciences, 6
Szapocznik, J., Santisteban, D., Rio, A., Perez-Vidal, A., & Kurtines, W. M. (1986).Cross cultural training for mental health professionals.
Szapocznik, J., Santisteban, D., Rio, A., Perez-Vidal, A., Santisteban, D., & Kurtines, W. M. (1989).Hispanic Journal of Behavioral Sciences, 11