# Risk and Protective Factors and Developmental Models in the Etiology of Substance Abuse

Researchers have known for some time that certain conditions in the lives of some children and adolescents make it more likely or less likely that they will use alcohol, tobacco, and illicit drugs. These conditions are often referred to as either risk factors - conditions that increase the likelihood of substance abuse - or protective factors - conditions that prevent or modify risk factors or improve circumstances in the lives of adolescents, thereby reducing the likelihood of substance abuse. Researchers believe that it is necessary both to reduce risks and to enhance protective factors to maximize the prevention of adolescent substance abuse.

The most extensively studied risk and protective factors affecting adolescent onset of substance abuse have been described and categorized in a variety of ways during the past decade (Bry, 1995; Hawkins, Catalano, & Miller, 1992; Hawkins, Arthur, & Catalano, 1994; Kumpfer & Alvarado, 1995; Institute of Medicine, 1994; Rutter, 1987a; Turner, 1995; Werner, 1986, 1989, 1992). Based on this research, a number of etiological models have been developed to explain the relationship between the presence or absence of these factors and the development of substance abuse and other adolescent problem behaviors. The prevention approaches described in chapter 3 are built on these studies of risk and protective factors and on current etiological models.

To maximize the prevention of adolescent substance abuse, it is important both to reduce known risks and to enhance protective factors.

## The Influence of Risk and Protective Factors

Risk and protective factors for adolescent substance abuse are not discrete traits or characteristics, but are complex factors that interact in dynamic ways. As understanding of these interactions grows, researchers are generally reaching agreement on the following:

- Many influences in the lives of families and children determine the impact of risk and protective factors. These influences include the developmental level of the child, the degree of interaction among the risk and protective factors, the number that are experienced simultaneously, their intensity and duration, and the interactions among the risk and protective factors within families and with the larger environment.
- A core of risk factors is common to several adolescent problem behaviors. Because several risk factors for substance abuse are also risk factors for delinquency - dropping out of school, teen pregnancy, and other serious problems of adolescence - addressing the common core of risk factors can affect these and other problems.
- Risk and protective factors operate in multiple domains. The ways in which risk and protective factors interact among different domains can increase or decrease the probability of substance abuse in adolescence. The major domains in which risk and protective factors operate include the following:
  - The child's genetic and biological makeup, behavior, and personality.
  - Family structure, management, and practices.
  - Environmental influences and conditions outside the family, such as school experiences, peer influences, the work and social milieus of parents, and community mores and values.

Some researchers refer to these domains as "a set of nested systems" (Bronfenbrenner, 1979; Szapocznik & Kurtines, 1993). For example, children are affected by the dynamics and interactions of the families in which they live, which are in turn influenced by the surrounding community environment. This point is discussed in more detail in the section on contextualism later in this chapter.

### Risk Factors and the Link to Substance Abuse

In many cases, a causal relationship between the risk factors described in this chapter and adolescent substance abuse has not been established. Rather, evidence that such a correlation exists is based on longitudinal observations of the presence of an identified risk factor during the onset of adolescent substance abuse. However, many researchers have concluded that even though the causal role of many risk factors is under investigation, it is worthwhile to aggressively address them in efforts to prevent adolescent substance abuse.

As described, the core risk factors identified in research thus far relate to the domains of the individual child, the family, and the larger environment, including the school, the neighborhood, and the community. Each of these domains is described below.

#### Individual Risk Factors: Biology, Behavior, and Personality

Investigators continue to examine the role of genetic and biological factors in substance abuse. Research has demonstrated that in some cases, children's antisocial and other problem behaviors can predict substance abuse, particularly when these problems exist at an early age. Further, the severity of adolescent drug involvement appears to correlate directly with the frequency of problem behaviors, including delinquency (e.g., interpersonal aggression, theft, and vandalism). The likelihood that antisocial and other problem behaviors (which are themselves predictors of substance abuse) will persist into adulthood increases with the variety, frequency, and severity of antisocial behaviors in childhood. Some of the behavioral and personality factors most commonly identified as possible risks for the onset of substance abuse are as follows:

- Antisocial and other problem behaviors, such as conduct disorder, attention deficit hyperactivity disorder (ADHD), and aggressiveness (particularly in boys).
- Alienation and rebelliousness.
- High tolerance of deviance and a strong need for independence.
- Psychopathology.
- Attitudes favorable to drug use.
- High-risk personality factors, such as
  - sensation seeking,
  - low harm avoidance, and
  - poor impulse control.

#### Family Risk Mechanisms

The interaction and communication of parents, parents and children, and siblings play an important role in creating, exacerbating, or ameliorating the risk of substance abuse. Researchers have explored many of the circumstances and characteristics of families that predispose children to this risk. These examinations have led to several categorizations and groupings of risk factors, as well as hypotheses about various paths that lead to substance abuse. The family risk factors most commonly documented in the research literature fall into the following categories:

##### Family Behavior Concerning Substance Abuse

The likelihood of substance abuse by children increases when their parents abuse substances, either privately or in the presence of the children; when parental attitudes are perceived by the children as permissive toward youths' substance use; or when siblings (particularly older brothers) use drugs.

##### Family Management and Parenting Practices

Many behaviors and attitudes on the part of parents have been correlated with higher risk for children's substance abuse. These include overinvolvement of one parent and distancing by the other, low parental educational aspirations for children, and unclear or unrealistic parental expectations for children's behavior, especially as these expectations relate to the children's developmental level. Poor disciplinary techniques have been linked to the risk for substance abuse, such as a lack of or inconsistent discipline or excessively harsh punishment. The quality of the mother's relationship with the child has also been the subject of studies, indicating that the following parenting practices predispose children to substance abuse:

- Low maternal attachment.
- Lack of maternal involvement in children's activities.
- Cold, unresponsive, underprotective attitudes on the part of the mother.
- Maternal use of guilt to control children's behavior.

##### Family Conflict

Numerous studies have shown that conflict among family members is a strong predictor of delinquency and antisocial behavior, including substance abuse. A nontraditional family structure (i.e., single-parent household or "blended" family of parents and children from current and past unions) does not appear to be as strong a predictive factor as conflict among family members.

##### Physical Abuse

Perpetration of physical abuse is a major risk factor for adolescent substance abuse as well as for other antisocial behaviors. The earlier the age when physical abuse is experienced, the greater the potential for negative effects. Although common sense would suggest that sexual abuse is also a risk factor, research has not yet addressed this issue.

#### Environmental and Contextual Risk Factors

The social, institutional, and economic contexts in which families live have a strong bearing on the extent of children's risk for substance abuse. In most instances, environmental contexts operate independently as risks for adolescent substance abuse (e.g., peer influences or academic failure). However, the environment can also interact with existing child and family risk factors to heighten children's predispositions to substance abuse. The environmental and contextual risk factors commonly cited in the research are as follows:

##### Influence of Peers

Rejection or limited acceptance of children by their peers, particularly in the early school grades, appears to increase the risk of school problems and delinquency, which are in turn risk factors for substance abuse.

##### Cultural and Social Norms and Laws

Certain trends in social norms for substance abuse, as well as laws governing the availability and use of both legal and illegal substances, increase children's risk for substance abuse. Such trends include poor enforcement of the minimum purchase age for alcohol and tobacco products, social norms condoning use, and a proliferation of alcohol and tobacco product advertisements.

##### Poverty

Although the extent of economic well-being plays a role in the risk for substance abuse, poverty appears to increase this risk only when it is extreme and only in children with behavior problems or other risk factors. Children from families with high socioeconomic status generally have a lower than average rate of delinquency, while high population density, overcrowding, and poor housing appear to contribute to antisocial behavior and delinquency, which are risk factors for substance abuse.

##### Neighborhood Disorganization

Studies explicitly examining the relationship between "neighborhood disorganization" and substance abuse are scarce, but a number of environmental factors relating to neighborhoods and communities have been identified as contributing to delinquency and drug trafficking. These factors include deterioration of the physical state of the neighborhood, lack of a sense of community, a high crime rate, poor visibility of public places, and high mobility and transience. Deteriorating neighborhood conditions are sometimes due to the withdrawal of economic investments and jobs and the accompanying loss of a tax base. Neighborhood disorganization appears to hinder the ability of parents to instill prosocial values in their children - values that could help ward off delinquency and substance abuse.

##### Failure to Achieve in School

Academic failure, especially in the late elementary grades, increases the risk for substance abuse in adolescence. This is true regardless of whether school failure is due to behavior problems, truancy, learning disabilities, poor school environment, or other causes. Intellectual ability, however, has not been found to relate directly to an avoidance of substance abuse. In fact, some studies have shown a positive correlation between high intelligence and some types of substance abuse (Hawkins et al., 1992).

### The Role of Protective Factors in Substance Abuse Prevention

Even when risk factors are present, they are not precise predictors of the development of unwanted behaviors. Most children exposed to the risk factors described above do not, in fact, develop substance abuse problems as adults. Many of these children successfully negotiate the stages of childhood and adolescent development, possibly experimenting with substance use, without becoming chronic abusers. Investigators studying the etiology of substance abuse have attempted to identify and define the characteristics of these resilient children's personalities, families, and social environments, characteristics that appear to protect them from circumstances that could otherwise lead them to engage in substance abuse.

Factors that protect against adolescent onset of substance abuse have been far less extensively studied than have the risk factors that may lead to it. Researchers have hypothesized, however, that this protection is not merely the absence or opposite of risk factors, but rather the presence of positive influences that supplant, prevent, or counteract the risks. Protective mechanisms can interact with existing risk factors to prevent, modify, or moderate their effects. Protective mechanisms can also interact with each other to strengthen their protective effects (Hawkins et al., 1994; Rutter, 1987a). For example, the absence of a nurturing parent (a risk factor) could be counteracted by the presence of a nurturing grandparent or family friend (a protective factor). A child's strong bonding with his or her mother (a protective factor) can enhance that child's academic achievement in school (also a protective factor).

The best researched protective factors have also been categorized as individual and personality characteristics, family characteristics, and environmental factors. Protective factors are also frequently explained using the construct of resilience, an emerging area of research discussed in chapter 5.

#### Protective Individual and Personality Characteristics

Protective mechanisms relating to individual characteristics, as identified and described in the literature, include the following:

- A positive temperament or disposition.
- A broad repertoire of social coping skills.
- Belief in one's self-efficacy and the ability to adapt to changing circumstances.
- A positive social orientation.

As stated earlier, the role of intelligence as a protective factor against substance abuse remains unclear. In fact, high intelligence has in some cases been found to correlate with certain types of adolescent substance abuse. However, a number of researchers have found that intelligence can be a protective factor against severe childhood stresses, juvenile delinquency, and incompetency as an adult (Garmezy, 1993; Kumpfer, 1993; Werner, 1986). Because of the association between juvenile delinquency and substance abuse in adolescent behavior, it could be inferred that intelligence is therefore also a protective factor against substance abuse, but the dynamics of this relationship have not yet been demonstrated by research.

Because some individual protective mechanisms (e.g., positive temperament) are influenced by hereditary traits, they are not always directly amenable to prevention interventions. However, identifying and understanding these traits may make it possible to teach parents and children how to cope with and compensate for characteristics that pose risk. Some researchers have suggested that successful coping can in and of itself be a protective mechanism (Rutter, 1987a).

#### Protective Family Characteristics

Research indicates that two types of family-related factors can protect against the risk of substance abuse: (1) cohesion, warmth, and attachment (bonding) with one or both parents during childhood and (2) parental supervision of daily activities and conduct.

The importance of cohesion, warmth, and bonding as protective mechanisms was illustrated in a study by Richters and Martinez (1993), in which children attending elementary school in a Washington, DC, neighborhood characterized by violence were assessed to identify early predictors of adaptational success or failure. The researchers found that, despite being exposed to similar levels of violence in their neighborhoods, the children exhibited varying degrees of adaptational success and failure (defined by academic performance and reports of behavior by their parents). The children's degree of success or failure was determined by characteristics of their home lives. The risk of adaptational failure increased only when external adversities threatened the stability and safety of the children's homes.

Contrary to many popular assumptions about parents' lack of influence on adolescents, parental monitoring of adolescent substance abuse has been found to be a significant deterrent to substance abuse for adolescents across many demographic groups and cultures (Dishion, Reid, & Patterson, 1988; Ensminger, 1990; Richardson et al., 1989). Parental monitoring is particularly effective in middle childhood, when children may be vulnerable to initiating substance abuse and associating with deviant peers - when monitoring is accompanied by positive methods of behavior management and by family bonding and warmth (Catalano et al., 1992; Chilcoat, Dishion, & Anthony, 1995).

#### Protective Environmental Factors

The environmental contexts in which families live have a significant influence on children's lives and, when unfavorable, have the potential to predispose them to substance abuse. Sources of emotional support outside the immediate family - particularly one or several close friends and an informal network of neighbors, extended family, peers, and elders - can help protect children who are exposed to other risk factors. Successful school performance and strong commitment to school are also important. The following external factors appear to prevent or reduce the effects of risks such as poverty, low education, and family conflict:

- A positive external support system.
- Formal and informal family supports and resources.
- Norms, beliefs, and behavioral standards against substance use.
- Successful school achievement and commitment to school.

## Etiological Models for the Development of Adolescent Substance Abuse

Etiological models for the development of adolescent substance abuse generally seek to explain the relationships among risk and protective factors, that is, to identify the patterns and principles underlying the way these factors interact to shape children's lives. They also help to explain observable patterns of substance abuse among adolescents and provide markers for its development. Many of the approaches developed and used to prevent substance abuse in children and youth, including those presented in chapter 3, are based on the etiological models described in this section.

Researchers have not often had the opportunity to intervene in the lives of families with young children and then follow these children to observe their experimentation and substance abuse patterns during adolescence. Therefore, many of the prevention approaches assessed in chapter 3 do not directly measure adolescent substance abuse, but rather evaluate factors that are important precursors of substance abuse, as identified by etiological models. An understanding of these models will therefore help practitioners plan programs that can affect these precursors.

The strength and association of risk and protective factors differ among groups by gender, ethnicity, culture, and social ecology or context. Local prevention program designers should not assume any one theory of causation for their target population, but should seek local data or locally tested theories on which to base prevention designs (Kumpfer & Turner, 1990--91).

### The Developmental Pathways Model

A wealth of research describes various models of the relationship between developmental risk factors and adolescent substance abuse (e.g., Baumrind, 1991; Block, Block, & Keyes, 1988; Brook, Whiteman, Gordon, & Cohen, 1989; Brook, Whiteman, Cohen, & Tanaka, 1991; Coombs & Coombs, 1988; Kazdin, 1992; Maguin, Zucker, & Fitzgerald, 1994; McMahon, 1994; Patterson, 1982; Rutter, 1987a, 1987b, 1989). For example, risk factors - such as poor parenting skills, adverse family and environmental conditions, and characteristics of the child (e.g., irritability and discipline problems) - can interact over time to lead to conduct problems and to subsequent substance abuse. Some investigators have attempted to identify the pathways this sequence of events takes. According to the developmental pathways model, the presence of individual, familial, or social risk factors in a child's life can predispose him or her to engage in negative behaviors, which may in turn lead to additional adverse events and circumstances - and further counterproductive interactions.

The developmental pathways model can be illustrated by the development of conduct problems that begin during childhood (in contrast to those that begin in adolescence, which are usually less severe). This developmental pathway may involve risk factors such as stressful family conditions, which, in interaction with poor parenting skills, reinforce child noncompliance and "teach" children to engage in aversive behavior, as described below.

The apparent mechanism underlying this process involves stressors, such as marital conflict or financial difficulties, that make it difficult for parents to set consistent limits for their children or to provide effective support for them. This difficulty is exacerbated when the children have characteristics such as irritability or hyperactivity and when parents lack effective parenting skills. In the absence of constructive guidance from their parents, the children can become increasingly noncompliant, aggressive, and impulsive. Parents who lack the skills to deal with this behavior may allow it to continue, thereby reinforcing its use by the children. Subsequently, the children may begin to use aversive behavior in their social interactions outside the family. In other words, children learn to use aversive and hostile behaviors to react to their home environment and eventually extend these hostile behaviors to school and peer interactions. In this way, the child develops antisocial behaviors in nearly all of his or her interactions over time (Conduct Problems Prevention Research Group, 1992). These antisocial behaviors place the child at high risk for initiating substance abuse.

This example does not account for all of the many possible variables in a given pathway, nor does it allow for the variety of positive circumstances that can break the cycle of failure or otherwise affect the outcome for the child. Therefore, the developmental pathways model also takes mitigating factors into consideration. Among these mitigators are genetic predisposition, biological manifestations, shaping of the environment, cognitive and social skills, self-esteem and self-efficacy, habits, cognitive sets (internal organization of one's personal traits), coping styles, and links between experiences (Rutter, 1989).

Such pathways may be set in motion throughout an individual's life or only during certain periods. Conduct problems, for example, may begin early and may result in a deviant lifestyle; may begin later, during adolescence, and may be less severe; or may develop temporarily in response to certain situations (Moffitt, 1993). The study of children over time, from childhood to early adulthood, has provided evidence of relationships or pathways leading from early conduct problems, accompanied by parental social dysfunction, to the subsequent development of late adolescent substance abuse (Brook et al., 1991).

Integral to the developmental pathways model is the view that windows of opportunity exist during childhood to arrest or prevent the development of aversive behaviors that lead to substance abuse, such as poor conduct. These opportunities are theorized to be present during transitional periods, such as the move from preschool to elementary school and from elementary school to middle school. According to this model, it is especially appropriate to deliver intensive interventions to children with conduct problems during the developmental stages in which these events occur (Conduct Problems Prevention Research Group, 1992).

### The Social Development Model

The social development model seeks to explain antisocial behaviors, which are themselves risk factors for substance abuse, by examining the socialization processes (the interaction of developmental mechanisms through relationships with family, school, and peers) that predict such behaviors. This model hypothesizes that all children progress through similar developmental processes, during which they may develop a predominance of either prosocial or antisocial behaviors, depending on how they experience socialization and the other influences affecting their development (Catalano & Hawkins, 1996; Catalano, Kosterman, Hawkins, Newcomb, & Abbott, 1996; Hawkins & Weis, 1985). Therefore, the social development model specifies the mechanisms by which identified risk and protective factors interact to give rise to either prosocial or antisocial behaviors (Catalano et al., 1996).

Interventions based on the social development model include the modeling of prosocial activities. For example, parents are taught to give consistent messages about substance abuse and to encourage adolescents' participation in activities that increase opportunities for prosocial interaction (Spoth, Redmond, Haggerty, & Ward, 1995).

The social development model holds that both prosocial and antisocial patterns of behavior are learned from the same socialization agents. These agents include the family, school, religious and community institutions, and peers. The processes by which social behavior patterns are learned include children's perceived opportunities for involvement and interaction with others, their degree of involvement in these interactions, their skills to participate in them, and their reinforcement from them. Children and adolescents typically experience both prosocial and antisocial influences and engage in both types of behavior during their development. According to the social development model, however, the predominant behavior of adulthood will depend on the influence that was dominant during childhood and adolescence. Youth who have primarily been exposed to prosocial influences are more likely to exhibit prosocial behaviors; those who have primarily experienced antisocial influences are more likely to exhibit antisocial behaviors (Catalano et al., 1996).

### The Social Ecology Model

Like the social development model, the social ecology model (Kumpfer & Turner, 1990--91) is based on the belief that an adolescent's interactions with social, school, and family environments ultimately influence substance abuse and other antisocial behaviors. The social ecology model, however, emphasizes the importance of increasing opportunities within the social environment for youth to develop social competencies and self-efficacy.

It is known that the immediate direct predictor of substance abuse among adolescents is association with antisocial peers and involvement in antisocial peer behavior. Through empirical testing of the social ecology model, however, Kumpfer and Turner found that the factor leading to an adolescent's selection of prosocial or antisocial peers was his or her self-esteem or perceived self-efficacy - and his or her bonding with the school as a prosocial environment that rewards students for achievement and promotes involvement.

According to this model, the interplay between a youth and his or her family climate also influences the youth's self-esteem and self-efficacy. Family climate is determined over time through interactions between children and parents as they socialize and bond. Thus, bonding with both the school environment and the family shapes perceived self-efficacy and subsequent choice of peers - which influences choices about substance abuse.

The social ecology model offers an explanation of the "buffering effects of positive family and school environments on involvement with negative peers" (Kumpfer & Turner, 1990--91, p. 456).

Positive interactions with family and school environments can have a positive effect on the choice of prosocial friends, which in turn can positively influence the adolescent's choices about substance abuse. Thus, prevention programs based on this model attempt to improve family and school environments to foster prosocial development. Preventing Substance Abuse Among Children and Adolescents

### Contextualism

Contextualism hypothesizes that all behavior must be understood within its context. "Context," however, is broadly defined to include not only interactions between a person and his or her immediate environment but those between the individual and the domains of family, school, peers, community, and the larger societal or global environment. The concept of contextualism has its source in the work of Urie Bronfenbrenner (Bronfenbrenner, 1986; Bronfenbrenner & Crouter, 1983) and is now incorporated in a model that attempts to explain adolescent substance abuse (Szapocznik & Kurtines, 1993).

Szapocznik and Kurtines (1993) have examined and applied the model of contextualism to adolescents' increased risk for substance abuse within the context of family conflicts. Working with Hispanic adolescents, Szapocznik and Kurtines observed that family conflict developed when these youths began to assimilate American cultural values, which were in many ways in opposition to the Hispanic values held by their parents. Using the contextualism model, the authors reframed the intergenerational conflict between the youth and their parents as "nested" in a cultural context. Thus, the family members were able to perceive cultural conflict as a common foe. Cross-alliances were fostered between parents and youth, who were encouraged to appreciate aspects of each other's cultural values that were meaningful to them.

Contextualism can provide a basis for interventions that can be implemented in multiple systems and environments (e.g., family, school, peer relationships, and cultural value systems), especially the natural systems in which adolescents live and operate (Borduin & Henggeler, 1990).

In a different setting, Conger et al. (1991) examined the relationship between the contexts of family economic means on the one hand, and family environment on the other. Their focus was the effect of economic hardship on adolescent alcohol use in midwestern families. Financial hardships were shown to lead to conflict between the parents and increased hostile behavior by the parents toward the children. Marital conflict, hostile behavior between parents and youth, and decreased parental control all contributed directly to the risk of alcohol use by these adolescents.

## Family-Centered Approaches to Prevention

The etiological models just described have been used by practitioners and researchers to develop prevention approaches directed toward substance abuse by youth. (Prevention approaches are groups of prevention activities that broadly share common methods and strategies, assumptions, and outcomes, as defined in chapter 3). Of these prevention approaches, three met the criteria for inclusion in this guideline: parent and family skills training, in-home support services, and family therapy (see appendix B for the inclusion criteria used to select the prevention approaches described in chapter 3 and for a description of prevention approaches not included in this guideline). From the review of the etiological models on which these approaches are based, several prevention trends emerged concerning the interrelationships and interactions among children, families, and the broader domains within which they exist, as follows:

- There is a trend away from focusing on individual behaviors of children in single domains and toward broad contextual functioning of families in multiple domains. Intervention research has broadened from addressing children's needs in discrete settings, such as just the school or just the family, toward addressing multiple domains involving the family, the school, and the community.
- There is a trend away from viewing the family as a self-contained and independent unit and toward viewing it as an interdependent unit. Increasingly, researchers are examining interactions not only among family members but among families and community networks and systems that affect families' capacities and outcomes at many levels.
- There is a trend away from intervening in child behavioral problems as isolated events and toward recognizing that children's behaviors are embedded in ongoing developmental and family processes. Research is focusing on the developmental stages and processes of children as they unfold in relationship to their families, recognizing the following:
  - Interventions must be appropriate to the age, sex, culture, and developmental processes of the individual child and may be more successful if introduced during children's earlier developmental stages.
  - Problems accumulate, reformulate, and reemerge throughout a child's development stages. Intervention researchers have interpreted this phenomenon as an indication that interventions are needed throughout all developmental stages and all environmental settings.

The three approaches addressed in this guideline use varying combinations of preventive measures, strategies, and settings. These characteristics, as well as the family members included in the intervention and the intended outcomes, are shown in table 2-1. The universal, selective, and indicated prevention measures referred to in the table, measures that relate to the child's degree of risk, are defined in chapter 3. The three prevention approaches are briefly described in the following paragraphs as an introduction to the detailed presentations in chapter 3.

Table 2-1: Key Features of Family-Centered Prevention Approaches

Prevention Approach | Prevention Measures Used | Family Members Included | Key Strategies | Outcomes | Setting
Parent and Family Skills Training | Universal Selective Indicated | Parent training targets parents only, possibly with children in separate sessions. Family skills training is held with both parents and children. Combined parent and family skills training targets both parents and children. | Teaches skills, sometimes in combination with support groups or counseling. | Strengthen family ties. Acquire or improve parenting skills. Improve child behavior. | Individual families or groups of families in clinic or classroom.
In-Home Support Services | Indicated | Entire family living in household. | Provides skills training, therapy, and support services. | Preserve and/or reunite family with problems of child abuse or neglect or antisocial behavior. Stabilize crises. Improve parenting skills to nurture children. Improve family functioning. | Individual families in the home and in the community.
Family Therapy | Indicated | Parents and children, sometimes including siblings or other family members. | Therapy. | Improve family functioning and dynamics to resolve or mitigate problems with child. | Individual family in a clinic or in home.

### Prevention Approach 1: Parent and Family Skills Training

Parent and family skills training seeks to reduce the risk factors and enhance the protective factors relating to family life and behavior. The interventions in this approach have as their objectives the following:

- Parent and family skills training to improve and strengthen family life.
- Promotion of healthy children within the family setting.
- Improvement of relationships between parents and children.
- Instruction to parents on addressing specific problem behaviors of their children.
- General improvement of the structure, functioning, and interaction of families.

Most interventions that use the approach of parent and family skills training are based on the social development or social ecology models, which stem from social learning and operant theories of behavior. Other parent and family skills training interventions are based on the developmental pathways and contextualism models.

Most parent and family skills training approaches work to strengthen ties within families by teaching parents how to model and reinforce positive behavior. Because of the emphasis on developing and enhancing skills, interventions within this approach are usually intended to help parents practice what they learn (either with their children or through role playing and other learning exercises) and to receive feedback from the results of their practice.

These approaches teach parents how to model and reinforce positive behavior in relationship to identified interactional, communication, problem-solving, and discipline problems, especially with children who are exhibiting antisocial and other problem behaviors (or who are at above average risk for these behaviors). By modeling social skills, teaching them to their children, and strengthening family ties, parents reduce the risk that their children will be influenced by antisocial and substance-using peers.

In addition to directing prevention measures to children and families with varying degrees of risk, interventions for family and skills training may or may not involve both parents and children, as follows:

- Parent training interventions may involve the parents without the children, or parents and children separately.
- Family skills training interventions include the parents and children in training sessions in a clinic or at home.
- Combined parent and family skills training can be conducted in a variety of ways. For example, separate sessions may be held for the parents alone and for the family as a whole. Alternatively, separate sessions may be held for parents, for children, and for the family as a whole.

### Prevention Approach 2: Family In-Home Support

Family in-home support is a prevention approach that addresses risk and protective factors by focusing on preserving families through intervention in the home. Such interventions are designed to help reunite families with children who have been placed in foster care or to alleviate crises that, left unaddressed, might lead to the out-of-home placement of children. This approach uses indicated prevention measures to support families at home through crisis-related services in response to immediate needs, longer range services to improve parenting skills and support child development, and support services such as respite care, health care, and housing (Kinney, Haapala, Booth, & Leavitt, 1990).

Depending on the combination of services and training provided to a family, in-home support may draw on any one or all of the four etiological models discussed earlier in this chapter. This approach also draws on an eclectic mixture of other approaches. For example, it may draw on the parent training approach to teach parenting skills, as well as on the approach of family therapy (described in the following section) to restore a very troubled family's structure and functioning.

### Prevention Approach 3: Family Therapy

Family therapy usually employs prevention measures to intervene in families with children or adolescents with recognized antisocial or other problem behavior. Most such families have high levels of conflict, and many live in highly stressful environments. Interventions based on this approach most often take place in a clinic setting and are usually delivered to an individual family rather than a group of families.

Although the family therapy approach as defined here addresses families in which children and adolescents are not yet abusing substances, in practice, this distinction may be difficult to uphold. Many researchers believe that delinquency, conduct problems, and substance abuse among adolescents often occur simultaneously - that where one condition exists, the others are likely to be present, even though not diagnosed. Thus, practitioners may often find that substance abuse is already present in adolescence, even when they are intervening for delinquency or conduct problems to prevent substance abuse.

The following paragraphs describe therapies that are representative of the interventions used in the family therapy approach. Although there is some overlap in the concepts on which these therapies are based, each is sufficiently distinct to warrant mention here.

#### Structural and Strategic Therapies

Structural and strategic therapies focus on altering the structure and functions of internal family dynamics. Their primary goal is not the achievement of deep insight into behavior, but a change in family interactions so that individual development is supported while a sense of belonging is preserved. By making a family's relationships more functional, its members are better able to solve the problem that created the need for therapy (Santisteban et al., 1995).

#### Multisystemic Therapy

Also referred to as family ecology therapy, multisystemic therapy recognizes that childhood problems exist in a broad social context that includes multiple domains - such as the family, the school, and the community - and that each of these domains affects the influence of the others; that is, they are bidirectional. Therapists using this intervention attempt to identify the relationships among systems that contribute to dysfunction in children and families. They work on improving children's social skills as well as altering the interactions of family members between and among these life domains. Multisystemic therapy is therefore designed to intervene directly in the systems and processes of the individual family, including parental discipline, family affective relations, peer associations, and school performance, which are known to be related to antisocial behavior in adolescents (Henggeler, Melton, & Smith, 1992; Henggeler et al., 1986).

#### Functional Family Therapy

Functional family therapists strive to help family members understand their interactions and relationships. Family members and their behaviors are seen as a highly interdependent set of relationships in which change in the behaviors of one family member affects all family members. Therefore, functional family therapy works to change the communication and behavior patterns of individuals to improve the ways in which relationships function within the family unit (Alexander & Parsons, 1982).

## Conclusion

The family-related events and conditions in the lives of children and adolescents that predispose them to substance abuse are multifaceted and complex. One must take into account the relationships between the child and the family; among family members; and among the child, the family, and the larger environment. Researchers are increasingly recognizing the importance of the risk and protective factors identified as precursors to adolescent substance abuse, even though they do not yet fully understand the causal nature of these relationships. Approaches that seek to reduce risks and enhance protective factors to prevent adolescent substance abuse are now widely recognized and used by prevention practitioners.

Although many models and theories exist to explain human and family behavior, most of the interventions described in chapter 3 draw on one or more of the four etiologic models described (the developmental pathways model, the social development model, the social ecology model, and contextualism) to explain the relationships between risk and protective factors and adolescent substance abuse. Chapter 3 presents detailed information about research and practice interventions in three prevention approaches for substance abuse (parent and family skills training, in-home support, and family therapy). Some interventions in these approaches do not specifically address substance abuse prevention but are directed at reducing the risks and enhancing the protective factors associated with adolescent substance abuse. As demonstrated in the next chapter, these interventions are often embedded in the efforts of community programs and organizations, such as schools, child behavior clinics, child development programs, family therapy programs, child welfare agencies, and churches - all organizations that are trying to meet the broader needs of families.

## References

Alexander, J., & Parsons, B. V. (1982).Functional family therapy
Baumrind, D. (1991).Journal of Early Adolescence, 11
Block, J., Block, J. H., & Keyes, S. (1988).Child Development, 59
Borduin, C. M., & Henggeler, S. W. (1990).Behavior disorders of adolescence
Bronfenbrenner, U. (1979).The ecology of human development
Bronfenbrenner, U. (1986).Developmental Psychology, 22
Bronfenbrenner, U., & Crouter, A. C. (1983).Handbook of child psychology, volume 1: History, theory, and methods
Brook, J., Whiteman, M., Gordon, A., & Cohen, P. (1989).Psychological Reports, 65
Brook, J. S., Whiteman, M., Cohen, P., & Tanaka, J. S. (1991).Genetic, Social, and General Psychology Monographs, 118
Bry, B. H. (1995).Parenting practices that reduce substance abuse risk: Challenge for prevention research
Catalano, R. F., & Hawkins, J. D. (1996).Delinquency and crime: Current theories
Catalano, R. F., Kosterman, R., Hawkins, J. D., Newcomb, M. D., & Abbott, R. D. (1996).Journal of Drug Issues, 26
Catalano, R. F., Morrison, D., Wells E. A., Gillmore, M. R., Iritani, G., & Hawkins, J. D. (1992).Journal of Studies on Alcohol, 53
Chilcoat, H. D., Dishion, T. J., & Anthony, J. C. (1995).American Journal of Epidemiology, 141
Conduct Problems Prevention Research Group. (1992).Development and Psychopathology, 4
Conger, R. D., Lorenz, F. O., Elder, G. H., Melby, J. N., Simons, R. L., & Conger, K. J. (1991).Journal of Early Adolescence, 11
Coombs, R. H., & Coombs, K. (1988).Journal of Chemical Dependency Treatment, 1
Dishion, T. J., Reid, J. G., & Patterson, G. R. (1988).Journal of Chemical Dependency Treatment, 1
Ensminger, M. E. (1990).Child Development, 61
Garmezy, N. (1993).Psychiatry, 56
Hawkins, J. D., Arthur, M. W., & Catalano, R. F. (1994).Crime and Justice, 8
Hawkins, J. D., Catalano, R. F., & Miller, J. Y. (1992).Psychological Bulletin, 112
Hawkins, J. D., & Weis, J. G. (1985).Journal of Primary Prevention, 6
Henggeler, S. W., Melton, G. B., & Smith, L. A. (1992).Journal of Consulting and Clinical Psychology, 60
Henggeler, S. W., Rodick, J. D., Borduin, C. M., Hanson, C. L., Watson, S. M., & Urey, J. R. (1986).Developmental Psychology, 22
Institute of Medicine. (1994).Reducing risks for mental disorders
Kazdin, A. E. (1992).Clinical Psychology Review, 12
Kinney, J., Haapala, D., Booth, C., & Leavitt, S. (1990).Reaching high-risk families: Intensive family preservation in human services
Kumpfer, K. L. (1993).Strengthening America's families: Promising parenting strategies for delinquency prevention
Kumpfer, K. L., & Alvarado, R. (1995).Drug abuse prevention with multiethnic youth
Kumpfer, K. L., & Turner, C. W. (1990--91).International Journal of the Addictions, 25
Maguin, E., Zucker, R., & Fitzgerald, H. (1994).Journal of Research on Adolescence, 4
McMahon, R. J. (1994).Journal of Consulting and Clinical Psychology, 62
Moffitt, T. E. (1993).Psychological Review, 100
Patterson, G. R. (1982).A social learning approach: Coercive family process
Richardson, J. L., Dwyer, K., McGuigan, K., Hansen, W. B., Dent, C., Johnson, D. A., Sussman, S. Y., Brannon, B., & Flay, B. (1989).Pediatrics, 84
Richters, J. E., & Martinez, P. E. (1993).Development and Psychopathology, 5
Rutter, M. (1987a).American Journal of Orthopsychiatry, 57
Rutter, M. (1987b).Handbook of infant development
Rutter, M. (1989).Journal of Child Psychology and Psychiatry, 30
Santisteban, D. A., Coatsworth, J. D., Perez-Vidal, A., Mitrani, V., Jean-Gilles, M., & Szapocznik, J. (1995).Brief structural/strategic family therapy with African American and Hispanic high risk youth
Spoth, R., Redmond, C., Haggerty, K., & Ward, T. (1995).Journal of Marriage and the Family, 57
Szapocznik, J., & Kurtines, W. M. (1993).American Psychologist, 48
Turner, S. (1995).Substance misuse in adolescence
Werner, E. E. (1986).Journal of Studies on Alcohol, 47
Werner, E. E. (1989).American Journal of Orthopsychiatry, 59
Werner, E. E., & Smith, R. S. (1992).Overcoming the odds: High-risk children from birth to adulthood