# Substance Abuse Problems and the Status of the American Family

Substance abuse, which has been called the number one preventable health problem in the United States (Robert Wood Johnson Foundation, 1993), places tremendous psychological and financial burdens on families. Because it is directly associated with emotional and physical problems, substance abuse often results in family disruption, financial problems, lost productivity, unemployment, and crime or legal problems (Liddle & Dakof, 1995).

Many of the changes that have taken place in American society in recent decades have created and perpetuated stressors for families. These stressors create an environment that places many children and adults at high risk for substance abuse. The fact that many of the adults who abuse substances are parents results in important implications for the health and well-being of their children.

Many of the recent changes in American society have created stressors that place families at increased risk for substance abuse.

An examination of these stressors and the patterns and trends of substance use in American society can provide perspective on the scope of the challenges facing families today. Therefore, this chapter presents detailed information on the breadth and extent of substance use in the United States, including current trends among youth and women. An overview of some of the changes that affect families, such as economic status, family structure, and the rates of violent crimes, is also presented. Chapter 2 expands and elaborates on this discussion in terms of factors that have been identified as increasing children's risk of developing substance abuse problems in their later years. Chapter 4 applies practical aspects of this information by describing ways to address substance abuse problems in the community.

Many of the statistics presented here to describe the prevalence of substance use and its consequences are derived from standardized national surveys. A description of the survey methods used and the populations surveyed are provided in exhibit 1-1.

Exhibit 1-1: Sources of Information on Substance Abuse

This chapter presents information based in part on standardized and regularly administered national surveys sponsored by the Federal Government to monitor trends of substance use in the United States.

General Population

- The National Household Survey on Drug Abuse (NHSDA) began collecting information on the use of alcohol, cigarettes, and illicit drugs in 1971 from a household sample that has subsequently been expanded to include the civilian noninstitutionalized U.S. population 12 years of age and over. Until 1991, the NHSDA was conducted under the purview of the National Institute on Drug Abuse (NIDA); in 1992, this responsibility was assumed by the Substance Abuse and Mental Health Services Administration.

Youth

- The Monitoring the Future Study is an annual school survey conducted each spring by the University of Michigan Institute for Social Research and is sponsored by NIDA. Until 1991, the stratified, random probability sample comprised only high school seniors; after 1991, the survey was expanded to include 8th and 10th graders.
- The Youth Risk Behavior Surveillance System (YRBSS) collects information from a representative sample of youth aged 12 to 21 years. Youth are surveyed on six categories of risk behaviors that contribute to the leading causes of morbidity and mortality in the United States, including use of alcohol, tobacco, marijuana, and cocaine. This survey began in 1990 under the sponsorship of the Centers for Disease Control and Prevention. Because the sensitive data collection procedures emphasize privacy, rates of substance use reported in the YRBSS are generally higher than those in other surveys.

Women

The National Pregnancy and Health Survey was initiated with funding from NIDA in 1992_1993 to provide information on the extent to which a random-probability sample of women who had just given birth to a live infant had used substances during pregnancy or during the 3 months before conception.

Criminal Offenders

The Survey of Inmates of Local Jails and the Survey of Inmates of State Correctional Facilities are sponsored by the Bureau of Justice Statistics to collect information on the use of drugs by offenders in the month before the index crime for which a conviction was obtained.

## Substance Abuse in the United States: The Extent of the Problem

"There are more deaths, illnesses, and disabilities from substance abuse than from any other preventable health condition. Of the two million U.S. deaths each year, more than one in four is attributable to alcohol, illicit drug, or tobacco use."

(Robert Wood Johnson Foundation, 1993, p. 8)

Although current rates of substance abuse in the United States are substantially lower than during the late 1970s, in the past few years there have been some reversals of this trend. This is particularly true among certain subgroups, such as adolescents, and in relation to certain drugs, such as marijuana. Irrespective of trends and fluctuations, the use of alcohol, tobacco, and illicit drugs is widespread in our society and is associated with an increased risk for a variety of health problems.

### Patterns of Substance Use in the General Population

The number of current users of any illicit drug has declined from over 25 million to 13 million since 1979 - a decline of nearly 50 percent. Changes in cocaine use have contributed to this trend. For example, the number of current users of cocaine among households has decreased from a peak of 5.7 million users in 1985 to 1.7 million in 1996 - a decline of 70 percent (Substance Abuse and Mental Health Services Administration [SAMHSA], 1997a). Also, the current use of marijuana is down from 23.8 million users in 1979 to 10.1 million in 1996, a decline of 58 percent (SAMHSA, 1997a). Figure 1-1 illustrates the estimates of past-month substance use among Americans aged 12 years and older during the period from 1979 through 1996 (SAMHSA, 1997a).

Figure 1-1: Estimate of Past-Month Substance Use Among U.S. Population 12 Years and Older, 1979--1996

Source: Substance Abuse and Mental Health Services Administration. (1997a). Preliminary estimates from the 1996 National Household Survey on Drug Abuse. Rockville, MD: Author, Office of Applied Studies.

The National Household Survey on Drug Abuse provides estimates of the prevalence of use of a variety of drugs among the general population. The following 1996 survey results highlight the prevalence of substance use within the past month, generally considered a measure of current use (SAMHSA, 1997b):

- Illicit drug use - An estimated 13 million Americans report using any illicit drug within the past month. (The number of current illicit drug users was at its highest level in 1979, with 25 million users.)
- Cocaine use - An estimated 1.75 million Americans report using cocaine within the past month. This is a decrease from a peak of 5.7 million in 1985.
- Heroin use - Approximately 216,000 Americans report using heroin within the past month, an increase from 68,000 in 1993.
- Alcohol use - An estimated 109 million Americans aged 12 and older report using alcohol in the past month. About 32 million engaged in binge drinking (five or more drinks on at least one occasion in the past month), and about 11 million were heavy drinkers (five or more drinks per occasion on 5 days or more in the past 30 days).
- Cigarette use - An estimated 62 million Americans were current smokers in 1996. This represents a smoking rate of 29 percent.

The effects of such substance use are seen in high rates of health problems, ranging from sexually transmitted diseases (STDs) to accidents and injuries (Kann et al., 1996). Dependence on alcohol and other drugs is also associated with psychiatric problems, including depression, anxiety, and antisocial personality disorder. The problems correlated with specific drugs are described in the following sections.

#### Alcohol

Although definitions vary, the National Health Interview Survey defines heavy drinkers as those who consume 2 or more alcoholic beverages per day or 14 or more per week. Chronic heavy use of alcohol is associated with liver disease, cancer, cardiovascular disease, and neurologic effects (blackouts, dementia, seizures, and hallucinations).

Alcohol is a factor in about half of all fatalities from motor vehicle crashes, homicides, and suicides in the United States. Families of heavy drinkers are more likely than others to be characterized by violence between spouses, child abuse, and a higher than average likelihood of raising children who themselves become heavy drinkers. Children in alcoholic families often exhibit emotional and adjustment difficulties, many of which are caused by the stress of living as children of alcoholic parents. These difficulties include aggressive behaviors, conduct problems, difficulties with peers, hyperactivity, and poor school performance (Robert Wood Johnson Foundation, 1993). Other problems are caused by serious conditions related to fetal alcohol syndrome, which is linked to alcohol consumption during pregnancy.

#### Tobacco

Tobacco use is the single most preventable cause of premature death in the United States. Use of tobacco products jeopardizes health in many ways and substantially increases health care costs. Tobacco-related illnesses are responsible for one in every five deaths in the United States and are a direct contributor to four of the five leading causes of death: Cardiovascular disease, cancer, cerebrovascular disease, and chronic obstructive pulmonary disease (U.S. Department of Health and Human Services [DHHS], 1993). Children whose parents smoke have more health problems than others, including respiratory infections and decreased lung growth (Robert Wood Johnson Foundation, 1993). Pregnant women who smoke increase their risk of miscarrying, delivering low-birth-weight babies, and experiencing obstetric complications (American College of Obstetricians and Gynecologists [ACOG], 1994;DHHS, 1991, 1993).

#### Illicit Drugs

In its survey of illicit drug use, the National Household Survey on Drug Abuse (NHSDA) includes marijuana and hashish; cocaine, including crack cocaine; inhalants; hallucinogens; heroin; and psychotherapeutic agents when used for nonmedical purposes. The 1996 NHSDA showed marijuana to be the illicit drug most commonly used in the general population, reported by about 80 percent of those aged 12 years and older who acknowledged illicit drug use within the month preceding the survey (SAMHSA, 1997a). Weekly cocaine use (defined in the NHSDA as use on 51 or more days within the past year) has remained relatively steady at a rate of 0.2 to 0.4 percent since 1985 (SAMHSA, 1997a, 1995a). Similarly, the rates for use of inhalants and nonmedical use of stimulants, sedatives, and tranquilizers have generally remained stable or declined in the last few years (SAMHSA, 1997a). While low, the rate of past-month use of hallucinogens doubled between 1994 (1.1 percent) and 1996 (2 percent).

Cocaine use can result in myocardial infarction, cardiac arrhythmia, and stroke and can lead to eating disorders. Crack cocaine use has been associated with an increase in STD rates among both adolescents and adults (DHHS, 1993; Johnson & Muffler, 1992). In pregnant women, cocaine can affect the fetus, increasing the risk of spontaneous abortion, pregnancy complications, fetal death, and congenital malformations (ACOG, 1994; Bingol, Fuchs, Diaz, Stone, & Gromisch, 1987; Handler, Kistin, Davis, & Ferre, 1991). Because they are highly addictive, cocaine and crack cocaine add significantly to the caseloads of drug treatment programs, the criminal justice system, public health facilities, and child protective custody and foster care systems.

#### Use of Multiple Drugs

Abuse of one substance seems to increase the likelihood for abuse of another. In the 1996 NHSDA, one-third of heavy drinkers also reported recent use of illicit drugs, compared with 5.3 percent of current but not heavy users of alcohol and only 1.9 percent of persons currently abstaining from alcohol (SAMHSA, 1997a). Similarly, current smokers are more likely than nonsmokers both to drink heavily and to use illicit drugs (SAMHSA, 1997a, 1995a).

### Patterns of Substance Abuse Among Women

Although substance abuse among women is less prevalent than among men, the health consequences for women may be greater. In particular, use and abuse of addictive substances by women in their childbearing years harms their own health and well-being as well as that of their children.

In many families, women are the primary caretakers of children, and the proportion of households headed by females is increasing. Substance abuse during a woman's childbearing years endangers her ability to successfully protect and nurture her children, however much she may wish to do so. The result is that children may be neglected, otherwise abused, or placed in foster care. Fears of criminal prosecution and of losing their children sometimes deter women with substance abuse problems from seeking treatment (Center for Substance Abuse Treatment, 1993).

Multiple Drug Use

- Among people aged 12 years and older who smoked, approximately 13 percent reported consuming five or more drinks on 5 or more days in the previous month, and 15 percent were current users of illicit drugs (SAMHSA, 1997a).
- In contrast, among nonsmokers aged 12 years and older, just 3 percent were heavy drinkers, and 3 percent were current users of illicit drugs (SAMHSA, 1997a).
- Use of combinations of alcohol, tobacco, and illicit drugs by pregnant women can make it difficult to determine the effects of individual drugs on the fetus, reducing the ability to prevent and treat health problems during pregnancy and after birth (DHHS, 1993).

#### Alcohol

Women who consume alcohol have historically been more stigmatized for it than men. As a result, many women, as well as clinicians and researchers, have been unwilling to acknowledge the existence of alcoholism in women. This has made it difficult to estimate the extent of the problem (Jacobs Institute of Women's Health, 1995). National surveys and studies that now include women are providing significant information about their use of alcohol. It is estimated that more than 2 million women in this country are heavy drinkers, and in the 1996 NHSDA, 44 percent of women reported use of alcohol within the past month (SAMHSA, 1997a).

Women are less likely than men to consume alcohol heavily: In the 1996 NHSDA, 9 percent of all men were estimated to be heavy drinkers, compared with only 2 percent of women (SAMHSA, 1997a). Even so, there is evidence that women who drink alcohol in amounts comparable to those consumed by men are likely to be more impaired, both immediately and over the long term (Jacobs Institute of Women's Health, 1995). Smaller quantities of alcohol are required to produce intoxication in women than in men because the body water content of women tends to be lower than that of men, resulting in more rapid alcohol diffusion (National Institute on Alcohol Abuse and Alcoholism [NIAAA], 1990a; National Institute on Drug Abuse [NIDA], 1993).

#### Tobacco

Although the rate of cigarette smoking has decreased overall in recent years for both men and women, this decline has been smaller among women. Smoking within the past month by females aged 12 to 17 years remained between 9.5 and 11.2 percent between 1988 and 1993, but has been increasing since 1992 (SAMHSA, 1993, 1994, 1995b). Among women over 12 years of age, 27 percent report smoking cigarettes within the past month (SAMHSA, 1997b).

Women who currently smoke are more likely than others to be separated or divorced, to have no more than a high school education, and to have a low income (Centers for Disease Control and Prevention [CDC] 1997b; Schoenborn & Boyd, 1989). In 1994, there were approximately 170,000 new cases of lung cancer in the United States, of which roughly 70,000 were in women (Friedberg & Kaiser, 1997). Lung cancer now exceeds breast cancer as the leading cause of cancer death in women (National Center for Health Statistics [NCHS], 1995).

Alcohol and Women

- Over 16 percent of pregnant women report drinking during the preceding month (Centers for Disease Control and Prevention, 1997a).
- A longitudinal study of alcoholic women estimated that their life span is reduced by 15 years because of disease, alcohol-related incidents, and suicides (Smith, Cloninger, & Bradford, 1983).
- Alcohol use during pregnancy has been identified as the leading preventable cause of birth defects (DHHS, 1991).

#### Illicit Drugs

Among females aged 12 years and older, 4.2 percent report using any illicit drug during the past month. Self-report of any illicit drug use is greatest among females aged 18 through 25 years (11 percent) and notable among those aged 12 through 17 years (8.9 percent) (SAMHSA, 1997b). An estimated 3.2 percent of pregnant women report using illicit drugs within the past month. However, women who gave birth within the past 2 years had a rate of 6.2 percent, suggesting that many women resume their drug use after giving birth. Similar patterns are seen for alcohol and cigarette use (SAMHSA, 1997a). The rates of self-report for using any illicit drug are higher among males for every age group and for all patterns (ever, past year, and past month) (SAMHSA, 1997b).

Psychotherapeutic drugs, including prescription stimulants, sedatives, tranquilizers, and analgesics, may be used nonmedically or in a manner inconsistent with prescribed use. These medications are often prescribed for legitimate therapeutic purposes, such as treatment of depression and anxiety. However, among women, the 1996 estimated prevalence rate for nonmedical use of any psychotherapeutic medication was 8 percent for lifetime use, 2.5 percent for past-year use, and 1.1 percent for past-month use (SAMHSA, 1997b). Among women who report any nonmedical use of psychotherapeutic medications, 0.6 percent report analgesic use, 0.4 percent report using tranquilizers, 0.1 percent report using sedatives, and 0.3 percent report using stimulants within the past month.

#### Prenatal Drug Exposure

Maternal substance use, notably the use of alcohol, cigarettes, marijuana, and cocaine, can have significant effects on the health of the newborn and possibly the older child as well. Most researchers and practitioners acknowledge, however, that effective nurturing and a supportive environment that addresses other risk factors in a child's life can make a significant difference for the child who was exposed to substance abuse in utero (Beckwith et al., 1994; Chasnoff, 1992).

Obstetric complications and poor pregnancy outcomes due to prenatal substance abuse have been well documented, as follows:

- Smoking during pregnancy is known to increase the risk of low birth weight (less than 2,500 grams), preterm birth (before 37 weeks), and miscarriage (pregnancy loss before 20 weeks) (ACOG, 1994; DHHS, 1991).
- Infants whose mothers used heroin or tobacco during pregnancy are at increased risk for sudden infant death syndrome (ACOG, 1994; Chasnoff, 1992).
- Heavy consumption of alcohol during pregnancy is associated with an increased risk of fetal alcohol syndrome, a condition comprising a constellation of physical and neurological deficits that includes growth retardation, facial deformities, and mental retardation (ACOG, 1994).
- The use of illicit drugs, particularly cocaine, has been linked to impaired fetal growth and neurobehavioral deficits (ACOG, 1994; Chasnoff, 1992).

Cigarette smoking in particular increases the likelihood of low birth weight and obstetric complications, such as problems with the placenta and preterm delivery (ACOG, 1994; DHHS, 1991). Older children of women who smoke are also at risk for health problems because of the effects of passive smoking, which contributes to serious upper respiratory problems among infants and young children (National Research Council, 1986; Office on Smoking and Health [OSH], 1986). Some data also suggest an association between maternal smoking (both during and after pregnancy) and an increased risk of sudden infant death syndrome (Schoendorf & Kiely, 1992). Quitting smoking before 16 weeks of pregnancy appears to offset many of these risks (ACOG, 1994).

Research on the possibility and extent of long-term effects of prenatal drug exposure is still in its early stages. Some research documentation exists to support the theory that problems in social, language, and cognitive development may appear as the child who was exposed in utero to drugs (particularly cocaine) grows older (Beckwith et al., 1994; Chasnoff, 1992; Chasnoff, Griffith, Freier, & Murray, 1992). Neurobehavioral problems in cocaine-exposed infants have to do primarily with motor behavior (reflexes and motor control and coordination), state control (the ability to move appropriately through the various states of arousal in response to outside stimuli), and orientation (the ability to interact actively with the external environment). Many of these infants exhibit irritability, sleeplessness, and difficulty in being nurtured (Chasnoff, 1992).

The developmental problems seen in older drug-exposed children appear to reflect the self-regulatory problems observed in the newborn. These children have difficulty regulating their behavior in response to complex stimuli and have low thresholds for overstimulation and frustration. They may feel overwhelmed by environmental stimuli, to which they may respond by withdrawing and/or losing control of their behavior, exhibiting hyperactivity and impulsiveness (Chasnoff et al., 1992).

In children exposed prenatally to cocaine and other drugs, Chasnoff et al. (1992) found that smaller head circumferences observed in infancy persisted through 3 years of age. One-third of drug-exposed children had delayed normal language development and problems in self-regulation and attention. Beckwith et al. (1994) studied a group of infants matched for similar family and socioeconomic backgrounds whose mothers had used phencyclidine (PCP) and/or cocaine during their pregnancies. The drug-exposed infants showed greater persistence of immature play strategies (patterns of disorganized and disruptive free play), less sustained attention, more deviant behaviors, and fewer positive social interactions than infants who had no prenatal drug exposure.

Researchers agree that, despite the possibility of long-term effects, protective factors can play a significant role in ameliorating the adverse consequences of maternal substance abuse. In their study, Beckwith et al. (1994) found that 25 percent of drug-exposed children were indistinguishable from control children in their play patterns. These drug-exposed children were found to have mitigating effects in their environment that helped counteract the adverse consequences of prenatal drug exposure. Mitigating factors included having mothers with more maternal sensitivity and responsiveness in the first year of life, having better attachment relationships to the primary caregiver, and having mothers with more years of education than other mothers. These results indicate the importance of a nurturing environment in protecting against the potentially debilitating effects of in utero exposure to drugs.

### Patterns and Consequences of Use of Specific Substances by Youth

Adolescence, typically a time of exploration in many areas of life, is a period when many young people first experiment with substance use. Young people today face increasingly complicated demands and expectations as they make the transition through adolescence to adulthood (Carnegie Council on Adolescent Development, 1995). Combined with social pressure to use drugs, these challenges are increasingly influencing many preteens and adolescents to experiment with drugs of abuse. The use of certain drugs, such as marijuana, among adolescents increased during the mid-1990s, but seems to be leveling off (see figure 1-2).

Figure 1-2: Recent Use of Selected Drugs by High School Seniors

Source: NIDA, 1996; University of Michigan Institute for Social Research, 1997. Note that outcomes by ethnicity are unavailable for recent years.

#### Alcohol

As in the total population, alcohol is the drug most frequently used by youth aged 12 to 17 years. By the 12th grade, most students (80 percent) have tried alcohol at least once. Slightly more than half of high school seniors report drinking within the past month, a fairly consistent pattern during the 1990s. During the 1970s and 1980s, the rates were substantially higher (NIDA, 1996). Even among 8th-grade students, more than half have tried alcohol, and a quarter have used alcohol within the past month (NIDA, 1996).

Chronic use of alcohol during adolescence can jeopardize physical, emotional, and social development during these formative years and compromise the transition to adulthood. Even infrequent intoxication can have acute consequences; the alcohol-related death rate is disproportionately high for those aged 15 to 24 years.

#### Tobacco

Cigarette use among high school seniors peaked in 1976 and 1977, dropped substantially until 1982, remained stable until about 1992, and has been gradually but steadily rising since then. Among high school seniors in 1997, 65 percent report having ever smoked a cigarette, 37 percent report smoking a cigarette within the past month, 25 percent report daily cigarette use, and 14 percent report smoking a half pack of cigarettes or more daily (University of Michigan Institute for Social Research, 1997). Most chronic smokers started when they were young teenagers, and many are starting even earlier. About one-quarter of high school seniors who have ever smoked report they smoked their first cigarette by the time they were in 6th grade (OSH, 1994). The many factors that encourage young people to begin using tobacco include peer pressure, parental and sibling smoking behavior, advertising and promotion by the tobacco industry, and the easy availability of cigarettes (OSH, 1994). Adolescents who begin smoking at young ages are at increased risk of becoming regular, heavy smokers and of contracting or dying from tobacco-related illness. Adolescent smokers also have higher rates of cough, shortness of breath, and other indicators of poor physical fitness than do nonsmokers (DHHS, 1993; OSH, 1994).

Heavy Drinking and Youth

- The rates of youth who consumed five or more drinks in a row within the past week are 15 percent, 24 percent, and 30 percent for students in the 8th, 10th, and 12th grades, respectively (University of Michigan Institute for Social Research, 1997).
- During the 1990s, a third or more of high school seniors report having been drunk during the past month (NIDA, 1996; University of Michigan Institute for Social Research, 1997; SAMHSA, 1995a, 1995b).

#### Inhalants

Every year, preteens and teenagers die of causes related to inhalation of substances such as lighter fluid, fabric protector spray, paint thinner, nail polish remover, and gasoline. Inhaling fumes from these substances may provide a quick high, with rapid dissipation and minimal hangover. Most inhalant abusers do not die of this practice, but it is impossible to predict when an otherwise healthy individual will suffer fatal consequences, even from a single episode of inhalant use. Inhalants can cause severe depression of the central nervous system, leading to cessation of breathing, cardiac arrest, coma, and death.

Chronic abuse of some inhaled substances, including glues, aerosols, and solvents, is associated with neurological damage and injury to the liver and kidneys. Some of the most deadly inhalants are the most widely used because they are found in many household products. Because they are inexpensive and widely available, they can be obtained by the very poor and the very young. In fact, inhalant use is highest during early adolescence (SAMHSA, 1995b).

#### Illicit Drugs

The rates of overall illicit drug use among youth declined substantially between the late 1970s and the early 1990s. Although current rates are generally half of the rates seen at the 1978--1979 peak, there was an increase in youth reporting use of any illicit drug during the 1990s. This trend appears to have leveled off (NIDA, 1996; University of Michigan Institute for Social Research, 1997). There have been different trends in relation to such illicit drugs as lysergic acid diethylamide (LSD) and other hallucinogens; tranquilizers and sedatives; stimulants, including methamphetamines and "Ecstasy" (MDMA, or 3-4-methylenedioxymethamphetamine); and cocaine.

Marijuana. Of particular concern is the pattern of marijuana use by youth. After 6 years of steady increases, marijuana use leveled off in 1997 among 8th grade students. Among high school students as a whole, the decelerating trend of marijuana use observed since 1985 started to reverse in 1992 and has continued on that trajectory. In 1997, for the first time in 6 years, there was an increase among 8th grade students in disapproval of marijuana use, and there was little further erosion of these attitudes among older students (University of Michigan Institute for Social Research, 1997).

Inhalant Use and Youth

- Inhalants are more popular among younger teens than older teens.
- Youth in 1997 reporting any inhalant use in the prior 12 months were 12 percent, 9 percent, and 7 percent in grades 8, 10, and 12, respectively (University of Michigan Institute for Social Research, 1997).

Regular use of marijuana may impair adolescents' ability to think, listen, express themselves, solve problems, and form abstract concepts. There is some evidence that students do not adequately acquire or retain knowledge when experiencing the effects of marijuana, and their motivation to learn may be altered (Nicholi, 1983). Further, marijuana smoking may have the same long-term consequences for the respiratory system, particularly pulmonary function, as does cigarette smoking (DHHS, 1993).

Illicit Drug Use and Youth

In 1997, one-third of 8th graders, almost half of 10th graders, and more than half of 12th graders reported that they had used an illicit substance at some time in their lives (University of Michigan Institute for Social Research, 1997).

##### Hallucinogens, Cocaine, Heroin, and Prescription Drugs

Experimentation with and more frequent use of illicit drugs other than marijuana is infrequent among youth. The rates of high school seniors who report using a hallucinogen during the past month has fluctuated between 2 and 4 percent during the 1975 through 1997 period. However, among high school seniors, rates of lifetime use of hallucinogens have risen from about 10 percent during the early 1990s to 15 percent in 1997, signaling an increase in experimentation (University of Michigan Institute for Social Research, 1997).

Intoxication with hallucinogens and PCP has been associated with unintentional injury. Use of cocaine and crack cocaine has never been prevalent among youth in school, but rates of experimentation with cocaine have been steadily (although modestly) increasing during the 1990s. Rates of heroin use among students are quite low, but they have risen significantly during the 1990s. Heroin is sometimes smoked in conjunction with cocaine and crack cocaine to prolong the euphoric effect. Also emerging in many areas of the country is the abuse of combinations of prescription drugs and of potent tranquilizers such as Rohypnol.

lllicit Drug Use and High School Seniors

- In 1997, 15 percent of high school seniors reported having tried hallucinogens at least once.
- Almost 9 percent of seniors reported having tried cocaine at least once.
- Slightly more than 2 percent of seniors reported having tried heroin at least once (University of Michigan Institute for Social Research, 1997).

##### Designer Drugs

Several sources indicate an increase in the use of so-called "designer drugs" (Office of National Drug Control Policy [ONDCP], 1995). These synthetic analogues of controlled substances are manufactured illegally for the specific purpose of abuse. They are created by making minor changes in the molecular structure of substances such as amphetamines (McCormick, 1989). These substances, sometimes termed "illicit synthetics," include 3-methylfentanyl, methamphetamine, PCP, and Ecstasy.

Because many of the illicit synthetics are clandestinely manufactured, contamination is relatively common and in some instances has been linked to neurodegenerative side effects (McCormick, 1989). Further, risk of overdose is pronounced because of their extreme potency; some are hundreds or even thousands of times stronger than the substance from which they are derived (Seymour, Smith, Inaba, & Landry, 1989).

Some illicit synthetics are typically used by teens and young adults (ONDCP, 1995). Several sources indicate that, because of their relatively easy availability and low cost, their use is expanding in major urban areas of the United States (ONDCP, 1995). Because some illicit synthetics are not included in national surveys, the prevalence of their use is difficult to determine. However, in 1997, the lifetime prevalence of Ecstasy was 7, 6, and 3 percent among students in the 12th, 10th, and 8th grades, respectively (University of Michigan Institute for Social Research, 1997).

### General Risks Associated With Substance Abuse Among Youth

Young people face unique risks related to substance abuse, in both the long and the short term. The effects of various substances can be more potent in adolescents than in adults because of their generally smaller body size and lower body weight. For this reason, they are at serious risk for a number of direct and indirect consequences, including intentional and unintentional injury. Three in four deaths in this age group are attributable to causes that are known to have a high association with alcohol use: motor vehicle crashes (35 percent) and other unintentional causes of injury (10 percent), homicide (17 percent), and suicide (13 percent) (DHHS, 1993). Additional risks relate to increased sexual activity, which can be the result of lowered inhibition brought on by the use of alcohol and illicit drugs (DHHS, 1993). Still other potential consequences are physical and emotional problems, learning disorders, poor school performance, and dropping out of school.

#### Early Sexual Activity

Beginning sexual activity at an early age is increasingly common among today's youth. CDC notes that more than half of all high school students have had sexual intercourse at least once, more than one-third have had sexual intercourse within the past 3 months, and nearly one-fourth have had sexual intercourse with four or more sex partners (Kann et al., 1996). Among the potential consequences of early sexual activity are contracting a sexually transmitted disease, including infection with the human immunodeficiency virus (HIV).

Sex and Youth

- More than half of all high school students have experienced sexual intercourse. Approximately 40 percent of girls and 36 percent of boys experienced sexual intercourse within the past 3 months.
- Approximately one-fourth of high school students used alcohol during their last sexual intercourse (CDC, 1996).

##### Sexually Transmitted Diseases

Of the 12 million new cases of STDs diagnosed each year, 86 percent occur in 15- to 29-year-olds (DHHS, 1993). Because of the nature of the cervical tissue during adolescence, girls who are sexually active are particularly susceptible to STDs. Among the most common STDs in young females are infections with chlamydia and human papillomavirus (HPV), which may cause genital warts. Some types of STDs are linked to an increased risk of cervical cancer.

##### HIV and AIDS

Adolescents are more likely to acquire HIV infection through heterosexual contact than through other modes of transmission (DHHS, 1993). Two-thirds of cases of acquired immunodeficiency syndrome (AIDS) in adolescents result from heterosexual contact. In 1994, the death rate from AIDS in 13- to 19-year-olds was 186 per 100,000 for males and 134 per 100,000 for females (NCHS, 1995). Among 13-year-olds, injectable drug use accounts for 22 percent of cases of HIV infection (DHHS, 1993). Seventeen percent of AIDS cases in 13- to 24-year-olds result from the use of injectable drugs (DHHS, 1993). AIDS among injected-drug users is the fastest growing cause of death among substance abusers: Two-thirds of new AIDS cases occur among injected-drug users and their sexual contacts (Robert Wood Johnson Foundation, 1993).

Pregnancy and Youth

- Each year since 1974, more than 1 million adolescents have become pregnant.
- Females under 20 years of age account for about one-fifth of abortions and 13 percent of births.
- Adolescent mothers are at increased risk for pregnancy complications, and their children are at increased risk for physical disability and infant death (CDC, 1997c; DHHS, 1993).

##### Unintended Pregnancy

Sexual activity in young females carries a particular risk for unintended pregnancy, which in turn increases the risk of induced abortion and death from childbearing. Approximately 40 percent of teenage pregnancies end in induced abortion (DHHS, 1993). In 1992, there were 61 births to every 1,000 females aged 15 to 19 years and 1.4 births per 1,000 females aged 10 to 14 years (NCHS, 1995). Childbearing at these young ages increases the risk of obstetric complications and maternal and fetal death. In 1992, 7 of every 100,000 live births to females under 20 years of age resulted in the death of the mother (NCHS, 1995).

#### Dual Diagnosis

In the late 1970s, mental health practitioners across the country were increasingly seeing young adults who were unresponsive to standard treatments for substance abuse. Treatment professionals became more aware of the relationship between substance abuse and psychiatric conditions, recognizing that substance abuse can cause psychiatric symptoms and can mimic psychiatric disorders or lead to their development, provoke their reemergence, and worsen their severity. Heightened attention was paid to individuals with coexisting psychiatric and substance-related disorders, popularly known as "dual diagnosis." The already difficult problem of treating mental illness became even more complex because of substance abuse. Even comparatively mild use of drugs of abuse can make the treatment of mental illness extremely difficult (Pepper & Ryglewicz, 1984). The mental disorders with the highest lifetime prevalence are related to substance abuse (Bourdon, Rae, Locke, Narrow, & Reiger, 1992).

#### The Gateway Hypothesis

Just as initiation of tobacco use often precedes that of alcohol, initiation of alcohol use usually precedes that of marijuana. The fact that use of these substances often precedes the first use of other drugs suggests support for the "gateway" hypothesis, which posits that the use of alcohol and tobacco at an early age is associated with progression to illicit drug use and greater involvement with drugs at older ages (DHHS, 1993; Robins & Przybeck, 1985).

## Substance Abuse: Critical Issues for Families and Children

Most Americans agree that the family is the central institution responsible for ensuring the safety of children and for providing the nurturing and guidance they need to become competent and contributing adults. In the last few decades, many changes have taken place in American society and in the characteristics of American family life. Some of these changes, such as widespread immunization programs, advances in medical technology, and more stringent safety regulations, are positive. Others, however, have contributed to the difficulties faced by parents in providing adequate nurturance and support for their children. Most families, including those under economic or other significant stressors, succeed in raising healthy children despite these difficulties. For some children, however, potential for a successful outcome plummets as family and community stresses escalate. Many children are raised in an environment that presents them with risks associated with substance abuse.

"Within our lifetime, dramatic changes have occurred in the structure of American families and of the workplace."

(Carnegie Council on Adolescent Development, 1995).

### Risks for the Family

#### Effects of Economic Status and Employment

The gap between family incomes for the affluent and the poor has widened in the last decade. Inequalities of income are now greater than at any time since the 1930s, and poverty rates for children as a group have continued to rise steadily since the 1970s. Low socioeconomic status is associated with a number of threats to children's health. Mental retardation, learning disorders, emotional and behavioral problems, and vision and speech impairments are more prevalent among children living in poverty than among those at higher socioeconomic levels (DHHS, 1991).

Economic Deprivation. Poverty is also a known risk factor for antisocial behaviors, including substance abuse (Hawkins, Catalano, & Miller, 1992). For many economically deprived youth, drug trafficking and substance abuse become the only perceived options for breaking the cycle of poverty and obtaining the material goods and resources their parents cannot afford to give them. Additionally, neighborhoods where people have little attachment to or investment in the community, in which social institutions are not strong, and in which there is low surveillance of public places have higher than average rates of adult and juvenile crime and drug trafficking.

Changes in economic status over the past two decades have been felt by many families with dependent children. The poverty rate for African-American families has remained substantially higher than that for White and Hispanic families. However, poverty has been growing most rapidly in these latter groups: Over the past 20 years, the rate of increase in poverty has been greatest for White and Hispanic families with dependent children.

Very young children are particularly likely to be living in poor families. More than one in four children under 6 years of age lived in poverty in 1994

##### Homelessness

The rate of homelessness has increased more rapidly among families with young children than in any other group over the past 20 years; today, one in four homeless persons is a child under 18 years of age (Children's Defense Fund [CDF], 1995). Negative experiences during childhood, particularly poverty, residential instability (e.g., nonparental placement or housing problems), and family problems (e.g., adult substance abuse or physical or sexual abuse), have been found to be related to a child's risk of becoming a homeless adult (Koegel, Melamid, & Burnam, 1995).

Studies of the homeless reveal that these populations report rates of substance abuse that are up to 25 times higher than those for populations living in households (Breakey et al., 1989; Fors & Rojek, 1991). Homeless alcohol abusers are at a substantially increased risk of trauma, victimization, frostbite, and tuberculosis (NIAAA, 1990b).

Urine tests of residents of homeless shelters in New York City in 1992 revealed a 54 percent prevalence of recent cocaine use and a 20 percent prevalence of recent marijuana use (New York City Commission on the Homeless, 1992). Drug use by homeless and runaway youth in shelters in the southeast United States was two to seven times higher in comparison to school samples (Fors & Rojek, 1991).

##### Numbers of Mothers in the Work Force

Another change affecting American families at all income levels is the growing number of mothers in the work force. Most mothers' employment is necessary for their economic survival as well as for their self-esteem and future security. Unlike families of a previous generation, however, many families now face the difficulty of finding quality child care and have less time to spend with and monitor their children (Dishion & Loeber, 1985; Dishion, Andrews, & Crosby, 1995; Farrington, 1978; McCord, 1979; Patterson, Reid, & Dishion, 1992). About 70 percent of youngsters with working mothers are cared for by an adult outside the immediate family. The number of "latchkey children," who care for themselves after school hours, is also growing.

The costs of child care can be a cause of concern and stress for low-income families. Already under significant stress, these families spend on average more than 20 percent of their income on child care, and families below the poverty line spend an even larger portion of their income - 27 percent - on child care (CDF, 1995).

Parents' concern about the quality of their children's care also contributes to the stress experienced by families. A 1995 study found that the quality of child care provided by most centers is poor to mediocre, and 12 percent of centers provide care so inadequate that it jeopardizes children's safety and development (CDF, 1996). Thirty-five percent of the family child care homes sampled in a Families and Work Institute survey were found likely to harm children's development because of poor-quality care (CDF, 1996).

#### Changes in Family Structure and Interactions

Changes in the structure of families and in the roles available to women have made it much more difficult for families to perform the traditional functions of nurturing and protecting children. In many cases, parents' time and opportunity for communicating with and supervising their children have also lessened. The degree to which families are unable to meet the basic developmental needs of their children, especially when this inability is manifested by incidents of maltreatment by parents or family members, has a direct correlation with adolescent substance abuse.

Women, Work, and Children

- Approximately 70 percent of mothers were in the labor force (either working or looking for work) in 1996.
- Overall, 54 percent of mothers with children under 1 year old were in the labor force during 1996, while 63 percent of mothers with children 2 years of age were in the labor force.
- Approximately 50 percent of unmarried mothers with children under 1 year of age were in the labor force, while 56 percent of married mothers with children the same age were in the labor force in 1996 (Bureau of Labor Statistics, 1997).

##### Single-Parent Families

One of the most frequently reported changes in families over the past two decades has been the increase in the number of children who live with a single parent. Children living in single-parent families are more likely to experience a number of negative outcomes. Some research has indicated that children in single-parent families are at greater risk of emotional problems and academic difficulties than those in intact two-parent families (Emery, 1988; McLanahan, 1988; McLanahan & Sandefur, 1994).

The growing number of single-parent households is due in part to the increasing proportion of disrupted marriages, which approaches 50 percent for those married before 1974 (NCHS, 1990). In addition to an increasing divorce rate, a major reason for the rise in single parenthood is childbearing by single women. In 1991 there were more than 1.2 million births to unmarried females, the highest number ever recorded in the United States (NCHS, 1993). However, the number and rate of births to unmarried women have since declined (Ventura, Martin, Curtin, & Matthews, 1997). A significant proportion of such births are to teenagers, 500,000 of whom give birth every year.

Teenage mothers face an above average risk of pregnancy complications, preterm birth, and low-birth-weight infants, and their infants are more likely to have physical disabilities and health problems than infants of older women (DHHS, 1993). Teen mothers are also more likely than are women in their 20s to receive either late prenatal care or none at all. Few young, single mothers are sufficiently mature or independent to assume the responsibilities of parenting. They are less likely than nonparent students to finish high school or to develop marketable skills. Female-headed households with dependent children have consistently experienced greater poverty than two-parent households. Within their peer group, single mothers are also more likely than others to be on welfare and to have entered into early marriages that end in divorce (CDF, 1995; National Commission on Children, 1991). The children of these mothers are themselves more likely than other children to become single parents at an early age (McLanahan & Sandefur, 1994).

Single-parent families also face more difficulties in monitoring the activities of and spending time with their children. Monitoring of children has been shown to be a protective factor in preventing and reducing risks for substance abuse (Hawkins et al., 1992). Conversely, lack of maternal involvement in a child's life has been found to be a risk factor for his or her later substance abuse (Kandel & Andrews, 1987).

Currently, 25 percent of children in this country live with only one parent (NCHS, 1994). Approximately three-quarters of these children experience poverty before they are 10 years old (CDF, 1995).

##### Child Abuse and Neglect

In 1993, 51 U.S. jurisdictions reported that more than 1 million children were found to be victims of maltreatment (National Center on Child Abuse and Neglect, 1994). Included among the types of maltreatment reported were the following:

- Neglect - 49 percent.
- Physical abuse - 24 percent.
- Medical and emotional neglect and other forms of maltreatment - 23 percent.
- Sexual abuse - 14 percent.

Nearly 9 of every 10 perpetrators of child maltreatment investigated by child protective services agencies were a parent or other relative of the victim; parents accounted for 77 percent of perpetrators (National Center on Child Abuse and Neglect, 1994). In recent years, substance abuse by parents has come to be seen as a major cause of child abuse and neglect. Yet in 1994, only 11 States reported having any new initiatives focused on parental substance abuse and its relationship to child abuse (CDF, 1995).

#### Parental and Sibling Substance Abuse

When children are raised in a family with a history of alcoholism, their own risk of having substance abuse problems increases (Hawkins et al., 1992). When parents use illegal drugs, are heavy users of alcohol, or are tolerant of their children's use of drugs, the children are more likely than otherwise to become substance abusers in adolescence.

Siblings are also role models for children's behavior. One study found that older brothers' drug behavior and attitudes were more strongly related to younger brothers' use than was parental modeling of substance abuse (Brook, Whiteman, Gordon, & Brook, 1988). (See chapter 2 for a discussion of family-related risk factors.)

### Risks for Children

#### Physical and Mental Health of Children

Children's health in the United States has apparently improved over the last several decades, as measured by reductions in infectious disease and infant mortality, increasing access to health care and immunizations, and more stringent safety regulations, such as those for car safety seats and safety belts. However, there are offsetting negative trends in the proportion of women receiving inadequate prenatal care, in the number of low-birth-weight babies, and in the number of pediatric cases of AIDS and injuries. In addition, wide disparities persist along lines of race and income in overall health status and some other child health indicators (e.g., rates of infant mortality, unintentional injury, immunization and hospitalization, and lead poisoning).

In 1993, nearly 20 percent of children aged 3 to 17 years were diagnosed as having a developmental delay, a learning disability, or an emotional or behavioral problem (CDC, 1994a).

##### Physical Health

A large percentage of the health problems in children currently seen by pediatricians involve developmental delay, learning difficulties, and emotional and behavioral problems. These conditions and others, including asthma, allergies, and eating disorders, were labeled "the new morbidity of childhood" in the mid-1970s (Haggerty, Roghmann, & Pless, 1975). Because these conditions may also have a psychosocial component, they do not easily fit into the framework of physical disease models. Some of these psychosocial problems have been identified as risk factors for substance abuse in adolescence (see chapter 2). The increasing prevalence of these conditions makes them of growing concern to health professionals and policymakers.

##### Mental Health

Increases in childhood behavioral disorders have been attributed to the growing proportions of children who experience parental divorce, poor mother-infant bonding, or poor infant stimulation; who were born outside of marriage; or who are raised in conflict-filled, low-income, low-education, and/or single-parent households. The etiology of most behavioral disorders, however, is not well understood. When considered with chronic physical conditions that are common in childhood, behavioral disorders clearly rank among the most prevalent health conditions (CDC, 1994a).

Increasingly, parents and educational systems are reporting that behavior problems in children and adolescents are major disruptive forces in the home and at school. These behavior problems may stem from the physical or mental health problems of children or from stresses that interfere with normal progression through childhood developmental stages. In many cases these factors are intertwined, and biological or genetic conditions set the stage for behavioral problems that may need special attention. Serious behavior problems in children often precede and are linked to substance abuse. (Chapter 2 provides a discussion of developmental pathways that may lead to adolescent substance abuse.) There is also concern that, although the behavioral problems of middle-class White youth are often handled within the mental health system, the same sorts of problems among low-income African-American or Hispanic youths often go untreated, only to be dealt with eventually by the criminal justice system (Office of Technology Assessment, 1986).

##### Suicide

Between 1950 and 1989, suicides among those 15 to 19 years of age quadrupled, from 2.7 to 11.1 per 100,000 (CDC, 1986a, 1995). Suicide is the third leading cause of death among 15- to 24-year-olds (Hammett, Powell, O'Carroll, & Clanton, 1992). Substance abuse is associated with this rapid escalation in the suicide rate, as are mental illness; impulsive, aggressive, and antisocial behaviors; adverse family influences; severe stress in school or social life; and sociocultural changes (CDC, 1995; National Commission on Children, 1991).

#### Declining Participation in School

Level of education is increasingly recognized as an important correlate of substance abuse. Heavier use tends to occur among those who are less well-educated (Robert Wood Johnson Foundation, 1993). About 30 percent of all students entering high school do not graduate within the next 4 years. (CDF, 1995).

##### Difficulty in Academic Achievement

Many youngsters do not develop the skills and habits necessary to keep up with classmates and complete their education. Such achievement problems may result from early behavior problems, learning disabilities, inadequate teaching methods, or other problems. Beginning in the late elementary grades, academic failure increases the risk of both early substance abuse and delinquency. It appears that the experience of school failure itself increases the risk of problem behaviors (Hawkins et al., 1992).

In addition, some studies indicate that successful school performance is associated with a decreased likelihood of frequent substance abuse:

Successful school performance is a protective factor mitigating against escalation to a pattern of regular marijuana use. Working toward strengthening the educational system would have many beneficial effects, including a potential reduction in the number of students who go on to abuse drugs (Kandel & Davies, 1992).

##### Dropping Out of School

Because most surveys of substance abuse and related risk behaviors among American youth do not regularly reach those who are not in school, the 1992 Youth Risk Behavior Surveillance Survey oversampled youngsters aged 12 to 19 years who had dropped out of school (CDC, 1994c). Risk behaviors for these children were compared with the risk behaviors of youth who remained in school. The survey found that all types of substance abuse increased with age, but out-of-school adolescents were significantly more likely than those in school to report recent use of a psychoactive substance. (The rate of episodic binge drinking, however, did not vary by school enrollment status.)

Youth and Mental Health

- An estimated 12 to 15 percent of youth have a mental disorder.
- The proportion of children receiving psychological assistance increased by 80 percent between 1981 and 1990.
- The most frequently diagnosed disorders in children are disruptive behavior, including attention deficit hyperactivity disorder and conduct disorder. Children with either of these conditions are at above average risk for developing substance abuse problems in adolescence (see chapter 2).
- More than 5 percent of all school-aged children have diagnosable depression or anxiety and serious learning difficulties (National Commission on Children, 1991).

#### Crime and Safety Problems

Violent crime consists of murder and manslaughter, rape, robbery, and assault. In the United States, there were approximately 1,800,000 violent crimes during 1995, a rate of 685 per 100,000 inhabitants (Federal Bureau of Investigation, 1996). Violence has increasingly become not only a premeditated tool used to commit criminal acts but also a response to emotional distress and interpersonal conflict. For this reason, and because of the substantial increase in the number of violent acts, violence - previously seen as the primary responsibility of the fields of law enforcement, social services, and mental health - has become a national public health priority.

Out-of-School Youth

- The school drop-out rate is particularly high in inner-city high schools, where as many as half of students do not graduate (Johnson & Muffler, 1992).
- Out-of-school adolescents are more likely than their student counterparts to have had sexual intercourse (70.1 versus 45.4 percent) and to have had four or more sexual partners (36.4 versus 14.0 percent), but are not more likely to use condoms.
- Youth who are not in school are also more likely than their student counterparts to take rides with drivers who have been drinking, to get involved in physical fights, and to carry a dangerous weapon (CDC, 1994b, 1994c).

Nonfatal injuries seen most frequently in emergency facilities include gunshot and knife wounds, broken bones, and lost teeth. The economic, political, and social disenfranchisement of inner cities is linked to the proliferation of crimes and drug trafficking, especially by youth in low-income communities. Rates of injury from violent and abusive behavior are highest among males, African Americans, people aged 19 to 24 years, those who are separated or divorced, those living in poverty, and residents of inner cities (Harlow, 1989). The most frequent victims of rape are women who are young, unmarried, and have a low income. The rates of rape and attempted rape, however, are difficult to measure because it is estimated that only about half of all victims contact law enforcement officials to report the crime (Bureau of Justice Statistics, 1985). Homicide is the 11th leading cause of premature death in the United States. Most homicides are committed with a firearm and occur among or between acquaintances (CDC, 1986b). Poverty and the use, manufacture, and distribution of drugs have been identified as important factors associated with homicide. Among youth, intentional injury exacts a disproportionately high toll of deaths, and the problem appears to be worsening (DHHS, 1991). The age of children involved in serious crimes is dropping as guns become more readily available.

##### Delinquency

Although youth who become involved in delinquent behavior and substance abuse come from all social strata and vary markedly in personality, juveniles in the justice system are more likely to be male, poor, living in high-density areas, and from an ethnic minority population (Earls & Reiss, 1994). Many juveniles who enter the justice system have psychosocial deficits in their backgrounds. These risk factors stem from breakdowns in five influential domains in juveniles' lives: Neighborhood, family, school, peers, and individual characteristics (Hawkins & Catalano, 1992). The presence of risk factors such as community disorganization, availability of drugs and firearms, and persistent poverty make children more prone to involvement in delinquent behavior than if those factors were not present. Additionally, when a child's family life is filled with violence, problem behaviors, poor parental monitoring, and inconsistent disciplinary practices or maltreatment, the child's risk of delinquency increases. Youth exhibiting combinations of these deficits in multiple domains of their lives are at highest risk of delinquency.

There are several reasons why many youths who are involved with drugs enter the juvenile justice system. Substance abuse increases the likelihood that individuals will engage in risky, destructive, or even violent behavior. Youths who are addicted may commit crimes such as theft, drug trafficking (which does not necessarily correlate with addiction), or prostitution. These youths often come in contact with others who are involved in substance abuse and crime and who reinforce these behaviors. (See discussion of the social development model in chapter 2.)

Three research projects supported by the Office of Juvenile Justice and Delinquency Prevention found that substance use and involvement in delinquent behavior are clearly interrelated (National Consortium of TASC Programs, 1995). Further, across all age, gender, and ethnic groups, the seriousness of a youth's involvement in substance abuse increases with the seriousness of his or her involvement in delinquency, and vice versa. Many of the risk factors for substance abuse presented in chapter 2 are also risk factors for delinquency.

#### Early Onset of Substance Abuse

The age at which young people start experimenting with alcohol, tobacco, and illicit drugs is a powerful predictor of later substance abuse, especially if use begins before age 15 (Robert Wood Johnson Foundation, 1993). Those who begin using alcohol or tobacco when they are very young have a higher rate of heavy use later in life. This is cause for concern because, by the time they are in 8th grade, 70 percent of youth report having tried alcohol; 10 percent, marijuana; and 44 percent, cigarettes (Robert Wood Johnson Foundation, 1993). Although many young people experiment with alcohol, tobacco, and illicit drugs at an early age, many do not continue to use them in adulthood.

Homicide and Youth

- Although adults still commit 84 percent of all murders, the number of juveniles arrested for homicide increased by 168 percent between 1984 and 1993 (NCHS, 1995).
- In 1991, nearly half (49 percent) of homicide victims in the United States were males aged 15 to 34 years (NCHS, 1995).
- More adolescent boys die of gunshot wounds than of all natural causes combined (NCHS, 1995).
- The homicide rate among Blacks far exceeds that for non-Blacks of the same age and sex (CDC, 1986b).

## Conclusion

The negative consequences of substance abuse place an enormous burden on Americans - not only on individuals but also on families, communities, and society as a whole. The consistent view of health experts is expressed in a report by the New York State Anti-Drug Abuse Council (1989):

Evidence is overwhelming that alcoholism and drug abuse are inextricably linked to the most pernicious social, health, and economic problems facing Americans today. These problems include family violence and child abuse, increased health care costs, AIDS transmission, and decreased learning in school, among others.

This chapter has presented evidence about conditions that affect family life and point to increased risks associated with substance abuse. Although some data reflect improvements in these conditions for all families, there is a significant core of families under stress for whom conditions continue to be deeply troublesome. These are the families whose children are at greatest risk of engaging in antisocial behavior, including substance abuse. As discussed in chapter 2, risks are related in part to the degree of nurturing and support children receive from their families, as well as the support their families receive from their communities. In communities where many risk factors prevail, it is likely that there is an elevated rate of substance abuse among family members, including children.

Violent Crime and Youth

- Juveniles were responsible for 17 percent of all violent crimes in 1991.
- The estimated 122,900 arrests of juveniles in 1991 reported by the Violent Crime Index was the highest in history. A total of 3,400 arrests were made for murder, 6,300 for forcible rape, 44,500 for robbery, and 68,700 for aggravated assault (Allen-Hagen & Sickmund, 1993).

## Using This Guideline

The following chapters are presented at a level appropriate for those who already possess the necessary skills to implement the recommended actions or who have the ability to acquire these skills using extant resources in the field. This guideline is not prescriptive, but is based on the recommendations of a non-Federal Expert Panel. The substance abuse prevention approaches presented in the guideline should be implemented with careful attention to community needs and available resources in combination with the evidence analyzed through the Prevention Enhancement Protocols System (PEPS).

Seven major audiences have been identified for PEPS products:

1. State-level agencies - Single State agencies for substance abuse prevention and treatment and collaborating State-level agencies are primary audiences for the PEPS guidelines.
2. Substate agencies - In all States, substate agencies are involved to varying degrees in basic prevention planning and development functions. These substate agencies also constitute a primary audience of PEPS products.
3. Community-based programs - PEPS guidelines can address the guidance needs of programs ranging from dynamic grassroots efforts to projects affiliated with schools, churches, workplaces, or other organizations within the community, thus conserving State and local resources.
4. Individual practitioners - Certain prevention interventions will likely be of special interest to school principals and staff, youth leaders, health personnel, physicians, nurses, lay and religious leaders, and judicial personnel, among others. PEPS practitioner's guides and community guides are tailored specifically to the needs of these individuals.
5. Target groups - PEPS companion documents may also be developed to inform substance abuse prevention target groups about emerging prevention activities that focus on the community and to advise these groups of opportunities to participate in these projects.
6. Federal and national prevention program sponsors - Prevention guidelines may be useful to the many Federal and national programs that sponsor substance abuse prevention efforts across the country. Prevention concepts, recommended approaches, and resources needed for specific interventions are all possible topics of interest to these groups.
7. Prevention researchers - Each guideline in the PEPS series devotes considerable attention to identifying gaps in knowledge and areas for further research. To the extent that these observations reflect a consensus of researchers and practitioners in the field, they serve as a good starting point for setting research priorities.

## Contents of this Guideline

Chapter 2, Risk and Protective Factors and Developmental Models in the Etiology of Substance Abuse, uses three domains, or areas of influence, as the framework for a discussion of the factors that place youth at risk for substance abuse and the factors that play a protective role. The three domains are personal characteristics of the child, family conditions, and the social environment. The chapter proceeds to review several theoretical models that have been used to study the interaction of risk and protective factors and the impact they have on the likelihood of substance abuse.

Chapter 3, Analysis of Evidence and Recommendations for Practice, examines three approaches to the prevention of substance abuse among youth. Each approach is subjected to PEPS criteria for rigor and extent of existing research and practice evidence. Specific conclusions for each approach are presented in the form of four possible levels of evidence. The level-of-evidence statements are complemented by evidence-based lessons learned and recommendations for practice that draw on both the evidence and the insight of the Expert Panel.

Chapter 4, Program Development and Delivery of Family-Centered Prevention Approaches, provides guidance for community action in terms of assessment, planning, delivery, and evaluation. The chapter also focuses on special planning issues, including collecting data with reference to risk and protective factors, involving families and communities in program planning, and identifying resources in the community to support target families and their community.

Chapter 5, Emerging Areas of Research and Practice, discusses the constructs of resilience and family support. These constructs are relevant to family-centered approaches but were not included in this guideline's analysis of research and practice because of an insufficient body of evidence to meet PEPS criteria. In addition to a description of these constructs, the chapter identifies recent and ongoing research efforts and areas that require more research and development.

Six appendixes are included to augment readers' understanding of the PEPS process and the content of the guideline and to point out relevant areas of information and sources not covered by this guideline.

## References

Allen-Hagen, B., & Sickmund, M. (1993).Juveniles and violence: Juvenile offending and victimization
American College of Obstetricians and Gynecologists (ACOG). (1994).Substance abuse in pregnancy
Beckwith, L., Rodning, C., Norris, D., Phillipsen, L., Khandabi, P., & Howard, J. (1994).Infant Mental Health Journal, 15
Bingol, N., Fuchs, M., Diaz, V., Stone, R. K., & Gromisch, D. S. (1987). Journal of Pediatrics, 110
Bourdon, K. H., Rae, D. S., Locke, B. Z., Narrow, W. E., & Reiger, D. A. (1992).Public Health Reports, 107
Breakey, W. R., Fischer, P. J., Kramer, M., Nestadt, G., Romanski, A. J., Ross, A., Royall, R. M., & Stine, O. C. (1989).Journal of the American Medical Association, 262
Brook, J. S., Whiteman, M., Gordon, A. S., & Brook, D. W. (1988 1990).Journal of Genetic Psychology, 151
Bureau of Justice Statistics. (1985).The crime of rape
Bureau of Labor Statistics. (1997).Employment characteristics of families: 1996.
Carnegie Council on Adolescent Development. (1995).Great transitions: Preparing adolescents for a new century
Center for Substance Abuse Treatment. (1993). Pregnant, substance-using women (Treatment Improvement Protocol No. 2, DHHS Publication No. SMA 93-1998). Rockville, MD: Author.
Centers for Disease Control and Prevention. (1986a).Youth suicide in the United States, 1970--1980.
Centers for Disease Control and Prevention. (1986b).Homicide surveillance: High-risk racial and ethnic groups/Blacks and Hispanics, 1970 to 1983.
Centers for Disease Control and Prevention, National Center for Health Statistics. (1994a). Health of our Nation's children (DHHS Publication No. PHS 95-1519). Washington, DC: U.S. Government Printing Office.
Centers for Disease Control and Prevention, National Center for Health Statistics. (1994b).risksMorbidity and Mortality Weekly Report, 43
Centers for Disease Control and Prevention, National Center for Health Statistics. (1994c).Morbidity and Mortality Weekly Report, 43
Centers for Disease Control and Prevention, National Center for Health Statistics. (1995).Morbidity and Mortality Weekly Report, 44
Centers for Disease Control and Prevention, National Center for Health Statistics. (1996).Morbidity and Mortality Weekly Report, 45
Centers for Disease Control and Prevention, National Center for Health Statistics. (1997a).Morbidity and Mortality Weekly Report, 46
Centers for Disease Control and Prevention, National Center for Health Statistics. (1997b).Morbidity and Mortality Weekly Report, 46
Centers for Disease Control and Prevention, National Center for Health Statistics. (1997c).Morbidity and Mortality Weekly Report, 46
Chasnoff, I. J. (1992, August).Current Problems in Pediatrics,
Chasnoff, I. J., Griffith, D. R., Freier, C., & Murray, J. (1992).Pediatrics, 89
Children's Defense Fund. (1995).The state of America's children: Yearbook 1995.
Children's Defense Fund. (1996).The state of America's children: Yearbook 1996.
Dishion, T. J., & Loeber, R. (1985).American Journal of Drug and Alcohol Abuse, 11
Dishion, T. J., Andrews, D. W., & Crosby, L. (1995).Child Development, 66
Earls, F. J., & Reiss, A. J. (1994).Breaking the cycle: Predicting and preventing crime
Emery, R. F. (1988). Marriage, divorce, and children's adjustment. Newbury Park, CA: Sage.
Farrington, D. P. (1978).Aggression and antisocial behavior in childhood and adolescence
Federal Bureau of Investigation. (1996).1995 crime in the United States.
Fors, S. W., & Rojek, D. G. (1991).Journal of Drug Education, 21
Friedberg, J. S., & Kaiser, L. R. (1997).Seminars in Thoracic and Cardiovascular Surgery, 9
Haggerty, R., Roghmann, K., & Pless, I. B. (1975).Child health and the community
Hammett, M., Powell, K. E., O'Carroll, P. W., & Clanton, S. T. (1992). Morbidity and Mortality Weekly Report, 41
Handler, A., Kistin, N., Davis, F., & Ferre, C. (1991).American Journal of Epidemiology, 133
Harlow, C. W. (1989). Injuries from crime
Hawkins, J. D., Catalano, R. F. (1992).Communities that care: Action for drug abuse prevention.
Hawkins, J. D., Catalano, R. F., & Miller, J. Y. (1992).Psychological Bulletin, 112
Jacobs Institute of Women's Health. (1995).The women's health data book: A profile of women's health in the United States
Johnson, B. D., & Muffler, J. (1992).Substance abuse: A comprehensive textbook
Kandel, D. B., & Andrews, K. (1987).International Journal of the Addictions, 22
Kandel, D. B., & Davies, M. (1992).Vulnerability to abuse
Kann, L., Warren, C. W., Harris, W. A., Collins, J. L., Williams, B. I., Ross, J. G., Kolbe, L. J., & State and Local YRBSS Coordinators. (1996).Morbidity and Mortality Weekly Report, 45
Koegel, P., Melamid, E., & Burnam, A. (1995).American Journal of Public Health, 85
Liddle, H. A., & Dakof, G. A. (1995).Journal of Marital and Family Therapy, 21
McCord, J. (1979).Journal of Personality and Social Psychology, 37
McCormick, M. (1989).Designer-drug abuse
McLanahan, S. (1988).Focus, 2
McLanahan, S., & Sandefur, G. (1994).Growing up with a single parent: What hurts, what helps
National Center on Child Abuse and Neglect. (1994).Child maltreatment 1993: Reports from the States to the National Center on Child Abuse and Neglect
National Center for Health Statistics. (1990). Monthly Vital Statistics Report, 38
National Center for Health Statistics. (1993).Monthly Vital Statistics Report, 42
National Center for Health Statistics. (1994).Health, United States, 1993
National Center for Health Statistics. (1995).Health, United States, 1994
National Commission on Children. (1991).Beyond rhetoric: A new American agenda for children and families: Final report
National Consortium of TASC Programs. (1995). A public safety partnership: The criminal justice system and treatment: A compendium of recent research on substance abuse and crime. Silver Spring, MD: Author.
National Institute on Alcohol Abuse and Alcoholism. (1990a).Alcohol and women
National Institute on Alcohol Abuse and Alcoholism. (1990b).Seventh special report to the U.S. Congress on alcohol and health from the Secretary of Health and Human Services
National Institute on Alcohol Abuse and Alcoholism. (1993).Eighth special report to the U.S. Congress on alcohol and health
National Institute on Drug Abuse. (1996).National survey results on drug use from the Monitoring the Future Study, 1975--1995. Volume I: Secondary school students
National Research Council. (1986).Environmental tobacco smoke: Measuring exposures and assessing health effects
New York City Commission on the Homeless. (1992).The way home: A new directory in social policy
New York State Anti-Drug Abuse Council. (1989).The case for drug and alcohol treatment
Nicholi, A. M. (1983).Journal of American College Health, 32
Office of National Drug Control Policy. (1995, Spring).Pulse check: National trends in drug abuse.
Office on Smoking and Health. (1987).The health consequences of involuntary smoking: A report of the Surgeon General
Office on Smoking and Health. (1994).Preventing tobacco use among young people: A report of the Surgeon General.
Office of Technology Assessment. (1986).Children's mental health: Problems and services: A background paper
Patterson, G. R., Reid, J. B., & Dishion, T. J. (1992).Antisocial boys.
Pepper, B., & Ryglewicz, H. (1984).TIE Lines, 1
Robert Wood Johnson Foundation. (1993).Substance abuse: The Nation's number one health problem - Key indicators for policy
Robins, L. N., & Przybeck, T. R. (1985).Etiology of drug abuse: Implications for prevention
Schoenborn, C. A., & Boyd, G. (1989).Vital Health Statistics, 10
Schoendorf, K. C., & Kiely, J. L. (1992).Pediatrics, 90
Seymour, R., Smith, D., Inaba, D., & Landry, M. (1989).The new drugs: Look-alikes, drugs of deception, and designer drugs.
Smith, E. M., Cloninger, R., & Bradford, S. (1983).Alcoholism: Clinical and Experimental Research, 7
Substance Abuse and Mental Health Services Administration. (1993).Preliminary estimates from the 1992 National Household Survey on Drug Abuse
Substance Abuse and Mental Health Services Administration. (1994).National Household Survey on Drug Abuse: Population estimates 1993
Substance Abuse and Mental Health Services Administration. (1995a).Preliminary estimates from the 1994 National Household Survey on Drug Abuse
Substance Abuse and Mental Health Services Administration. (1995b).National Household Survey on Drug Abuse: Population estimates 1994
Substance Abuse and Mental Health Services Administration. (1997a).Preliminary estimates from the 1996 National Household Survey on Drug Abuse
Substance Abuse and Mental Health Services Administration. (1997b).National Household Survey on Drug Abuse: Population estimates 1996.
University of Michigan Institute for Social Research. (1997).Monitoring the Future Study - 1997.
U.S. Department of Health and Human Services. (1991).Healthy People 2000: National health promotion and disease prevention objectives
U.S. Department of Health and Human Services. (1993).Public Health Reports, 108
Ventura, S. J., Martin, J. A., Curtin, S. C., & Matthews, T. J. (1997). Monthly Vital Statistics Report, 45