# Resource Guide

This resource guide provides the reader with suggestions for family-centered resources. The first section lists names and addresses of researchers and practitioners whose work was considered as evidence in evaluating the various intervention programs. Because detailed descriptions of their program planning and content are beyond the scope of this guideline (and often are not fully described in their published works), CSAP thought that those interested in implementing specific strategies may want to obtain more detailed information directly from these researchers and practitioners. The second section of this appendix lists Federal Government agencies and nongovernment organizations that provide information, resources, and guidance regarding family-related interventions and programs. Some of these organizations have information clearinghouses. This section also lists examples of foundations that provide support for family-centered interventions or research. Some of the foundations also provide educational materials for practitioners or the lay public.

## Researchers and Practitioners

Researchers
- Georgia Aktan, Ph.D.
- Needs Assessment Studies
- Michigan Department of Public Health
- Center for Substance Abuse Services
- 3423 Martin Luther King, Jr., Boulevard
- P.O. Box 30195
- Lansing, MI 48909
- James Alexander, Ph.D.
- Department of Psychology
- University of Utah
- Salt Lake City, UT 84112
- Arthur Anastopoulos, Ph.D.
- Department of Psychiatry
- University of Massachusetts Medical Center
- 55 Lake Avenue North
- Worcester, MA 01655
- Lew Bank, Ph.D.
- Oregon Social Learning Center
- 207 East Fifth Avenue, Suite 202
- Eugene, OR 97401
- Cole Barton, Ph.D.
- Psychology Department
- Davidson College
- Davidson, NC 28036
- Martha Bernal, Ph.D.
- Department of Psychology
- Arizona State University
- Box 871104
- Tempe, AZ 85287-1104
- Marianne Berry, Ph.D.
- School of Social Work
- University of Texas at Arlington
- Arlington, TX 76019
- Charles Borduin, Ph.D.
- Department of Psychology
- University of Missouri_Columbia
- 21 McAlester Hall
- Columbia, MO 65211
- Richard Catalano, Ph.D.
- Social Development Research Group
- School of Social Work
- University of Washington
- 146 North Canal Street
- Suite 211, XD-50
- Seattle, WA 98103
- Thomas Dishion, Ph.D.
- Oregon Social Learning Center
- 207 East Fifth Avenue, Suite 202
- Eugene, OR 97401
- Robert Felner, Ph.D.
- National Center on Public Education and Social Policy
- University of Rhode Island
- Shephard Building, Room 300
- 80 Washington Street
- Providence, RI 02903
- Matthew Fleischman, Ph.D.
- Family Research Associates
- 81 East 14th Street
- Eugene, OR 97401
- Rex Forehand, Ph.D.
- Institute for Behavioral Research
- Psychology Department
- Barrow Hall, Room 111
- University of Georgia
- Athens, GA 30602
- Donald Gordon, Ph.D.
- Department of Psychology
- Ohio University
- Athens, OH 45701-2979
- Louise Guerney, Ph.D.
- Individual and Family Consultation Center
- The Pennsylvania State University
- University Park, PA 16802
- David Hawkins, Ph.D.
- Social Development Research Group
- School of Social Work
- University of Washington
- 146 North Canal Street
- Suite 211, SC-50
- Seattle, WA 98105
- Scott Henggeler, Ph.D.
- Department of Psychiatry and Behavioral Sciences
- Medical University of South Carolina
- 171 Ashley Avenue
- Charleston, SC 29425
- Nicholas Ialongo, Ph.D.
- School of Hygiene and Public Health
- Department of Mental Hygiene
- Johns Hopkins University
- 624 North Broadway
- Baltimore, MD 21205
- Alan Kazdin, Ph.D.
- Department of Psychology
- Yale University
- P.O. Box 11A
- Yale Station
- New Haven, CT 06520-7447
- Michael Klein, Ph.D.
- Department of Educational Psychology
- University of Wisconsin_Milwaukee
- P.O. Box 413
- Milwaukee, WI 53201
- Patricia Knapp, Ph.D.
- Department of Psychology
- University of Maryland, Baltimore County
- 1000 Hilltop Circle
- Baltimore, MD 21250
- Rick Kosterman, Ph.D.
- Social Development Research Group
- School of Social Work
- University of Washington
- 9725 Third Avenue, NE., Suite 401
- Seattle, WA 98115
- Karol Kumpfer, Ph.D.
- Department of Health Education
- HPER N-215 (Annex 2007)
- University of Utah
- Salt Lake City, UT 84112
- Patricia Long, Ph.D.
- Department of Psychology
- Oklahoma State University
- 215 North Murray
- Stillwater, OK 74078
- Barton Mann, Ph.D.
- Department of Psychology
- University of Missouri_Columbia
- 210 McAlester Hall
- Columbia, MI 65211
- Hector Myers, Ph.D.
- Center for the Improvement of Child Caring
- 11331 Ventura Boulevard, Suite 103
- Studio City, CA 91604
- Gerald Patterson, Ph.D.
- Oregon Social Learning Center
- 207 East Fifth Avenue, Suite 202
- Eugene, OR 97401
- John Reid, Ph.D.
- Oregon Social Learning Center
- 207 East Fifth Avenue, Suite 202
- Eugene, OR 97401
- Daniel Santisteban, Ph.D.
- Center for Family Studies
- Department of Psychiatry and Behavioral Sciences
- University of Miami School of Medicine
- 1425 NW. 10th Avenue
- Miami, FL 33136
- Richard Spoth, Ph.D.
- Social and Behavioral Research Center for Rural Health
- Center for Family Research in Rural Mental Health
- Iowa State University
- ISU Research Park
- Building 2, Suite 500
- 2625 North Loop Drive
- Ames, IA 50010
- Fred Springer, Ph.D.
- EMT Associates, Inc.
- 771 Oak Avenue Parkway, Suite 2
- Folsom, CA 95630
- José Szapocznik, Ph.D.
- Department of Psychiatry
- University of Miami School of Medicine
- University of Miami
- 1425 NW. 10th Avenue
- Miami, FL 33136
- Ronald Thompson, Ph.D.
- Program Planning, Research, and Evaluation
- Common Sense Parenting Program
- Father Flanagan's Boys Home
- Boys Town, NE 68010
- Richard Tremblay, Ph.D.
- Research Unit on Children's Psychosocial Maladjustment
- University of Montréal
- 750 Gouin Boulevard East
- Montréal, Québec, Canada H2C 1A6
- Robert Wahler, Ph.D.
- Department of Psychology
- 227 Austin Peay Building
- University of Tennessee
- Knoxville, TN 37996
- Elaine Walton, Ph.D.
- College of Social Work
- Ohio State University
- 1947 College Road
- Columbus, OH 43210
- Carolyn Webster-Stratton, Ph.D.
- Parenting Clinic
- School of Nursing
- Box 354801
- 1107 NE. 45th Street, Suite 305
- University of Washington
- Seattle, WA 98105-4631
- Peter Wilson, Ph.D.
- Department of Psychology
- University of Sydney
- Sydney, N.S.W. 2006, Australia
- Sharlene Wolchik, Ph.D.
- Department of Psychology
- Arizona State University
- P.O. Box 871104
- Tempe, AZ 85287-1108

Practitioners
- Stephen Bavolek, Ph.D.
- The Nurturing Program for Parents and Children
- Family Development Resources
- 27 Dunnwoody Court
- Arden, NC 28704-9588
- Bernell Boswell
- Families in Focus Program
- The Cottage Program International
- 57 West South Temple, Suite 420
- Salt Lake City, UT 84101-1511
- Herbert Callison
- Kansas Family Initiative
- Kansas Department of Social and Rehabilitation Services
- P.O. Box 47054
- Topeka, KS 66647
- Eileen Carroll
- In-Home Care
- California Department of Social Services
- Office of Child Abuse Prevention
- 744 P Street, Mail Slot 19-82
- Sacramento, CA 95814
- Mary Heckenliable
- Intensive Family Preservation Program
- Hall Neighborhood House, Inc.
- 361 Bird Street
- Bridgeport, CT 06605
- Pat Mouton, M.S.W.
- Parenting for Prevention Program
- King County Division of Alcohol and Substance Abuse Services
- 999 Third Avenue, Suite 900
- Seattle, WA 98104
- Ted Strader
- Creating Lasting Connections
- Council on Prevention and Education: Substances
- 1228 East Breckenridge Street
- Louisville, KY 40204
- Linda Wheeler
- Families and Schools Together Program
- Family Service America
- 11700 West Lake Park Drive
- Milwaukee, WI 53224-3099

## Agencies, Organizations, and Foundations

Government Agencies
- Administration for Children and Families
- Administration on Children, Youth, and Families
- 330 C Street, SW., Room 2026
- Washington, DC 20201
- (202) 205-8347
- http://www.acf.dhhs.gov
- · Child Care Bureau
- 200 Independence Avenue, SW.
- Room 320F
- Washington, DC 20201
- (202) 401-6947
- · Children's Bureau
- 330 C Street, SW., Room 2070
- Washington, DC 20201
- (202) 205-8618
- · Child Welfare Bureau
- 330 C Street, SW., Room 2068
- Washington, DC 20201
- (202) 205-8618
- · Family and Youth Services Bureau
- 330 C Street, SW., Room 2046
- Washington, DC 20201
- (202) 205-8102
- · Head Start Bureau
- 330 C Street, SW., Room 2058
- Washington, DC 20201
- (202) 205-8573
- · National Child Care Information Center
- 301 Maple Avenue West, Suite 602
- Vienna, VA 22180
- (800) 616-2242
- http://www.ericps.ed.uiuc.edu/nccic
- · National Clearinghouse on Child Abuse and Neglect Information
- P.O. Box 1182
- Washington, DC 20013-1182
- (800) FYI-3366
- (703) 385-7565
- http://www.calib.com/nccanch
- · National Clearinghouse on Families and Youth
- P.O. Box 13505
- Silver Spring, MD 20911-3505
- (301) 608-8098
- · Office on Child Abuse and Neglect
- 330 C Street, SW., Room 2026
- Washington, DC 20201
- (202) 205-8586
- Center for Substance Abuse Prevention
- National Clearinghouse for Alcohol and Drug Information
- P.O. Box 2345
- Rockville, MD 20847-2345
- (800) 729-6686
- http://www.samhsa.gov/csap
- Indian Health Service
- Division of Clinical/Preventive Services
- 5600 Fishers Lane, Room 6A-55
- Rockville, MD 20857
- (301) 443-4644
- http://www.ihs.gov
- Juvenile Justice Clearinghouse
- P.O. Box 6000
- Rockville, MD 20850
- (800) 638-8736
- http://ncjrs.aspensys.com
- Maternal and Child Health Bureau
- Health Resources and Services Administration
- 5600 Fishers Lane, Room 18A-20
- Rockville, MD 20857
- (301) 443-0205
- http://www.hrsa.dhhs.gov
- · Division of Healthy Start
- 5600 Fishers Lane, Room 11A-13
- Rockville, MD 20857
- (301) 443-0509
- · Division of Maternal, Infant, Child and Adolescent Health
- 5600 Fishers Lane, Room 18A-30
- Rockville, MD 20857
- (301) 443-2250
- · Division of Services for Children With Special Health Needs
- 5600 Fishers Lane, Room 18A-27
- Rockville, MD 20857
- (301) 443-2350
- U.S. Department of Education
- 600 Independence Avenue, SW.
- Portals Building
- Washington, DC 20202-6123
- (800) 872-5327
- (202) 401-2000
- http://www.ed.gov
- · Even Start Family Literacy Program
- 600 Independence Avenue, SW.
- Portals Building
- Washington, DC 20202
- (202) 260-2777
- · Office of Elementary and Secondary Education
- Safe and Drug-Free Schools
- 600 Independence Avenue, SW.
- Portals Building
- Washington, DC 20202-6123
- (202) 260-3954
- U.S. Department of Health and Human Services
- Office of the Assistant Secretary for Planning and Evaluation
- 200 Independence Avenue, SW.
- Hubert H. Humphrey Building
- Room 415F
- Washington, DC 20201
- (202) 690-7858
- http://www.hhs.gov
- · Division of Children and Youth Policy
- 200 Independence Avenue, SW.
- Hubert H. Humphrey Building
- Room 450G
- Washington, DC 20201
- (202) 690-6461
- · Division of Public Health Policy
- 200 Independence Avenue, SW.
- Hubert H. Humphrey Building
- Room 442E
- Washington, DC 20201
- (202) 690-6870
- U.S. Department of Housing and Urban Development
- 451 7th Street, SW.
- Washington, DC 20410
- (202) 708-1420
- http://www.hud.gov
- · Community Connections Information Center
- Office of Community Planning and Development
- P.O. Box 7189
- Gaithersburg, MD 20898-7189
- (800) 998-9999
- · University Partnership Clearinghouse
- HUD USER
- P.O. Box 6091
- Rockville, MD 20849
- (800) 245-2691
- U.S. Department of Labor
- 200 Constitution Avenue, NW.
- Room S-1032
- Washington, DC 20210-0002
- (202) 219-8211
- http://www.dol.gov
- · Women's Bureau Clearinghouse
- 200 Constitution Avenue, NW.
- Room S3306
- Washington, DC 20210-0002
- (800) 827-5335
- · Work and Family Clearinghouse
- 200 Constitution Avenue, NW.
- Room 3317
- Washington, DC 20210-0002
- (202) 219-4486

Nongovernment Organizations
- American Association for Marriage and Family Therapy
- Research and Education Foundation
- 1133 15th Street, NW., Suite 300
- Washington, DC 20005
- (202) 452-0109
- http://www.aamft.org
- American Public Welfare Association
- 810 First Street, NE., Suite 500
- Washington, DC 20002-4267
- (202) 682-0100
- Center for Family Life in Sunset Park
- 345 43rd Street
- Brooklyn, NY 11232
- (718) 788-3500
- Children's Defense Fund
- 25 E Street, NW.
- Washington, DC 20001
- (202) 628-8330
- (202) 628-8787
- http://www.childrensdefense.org
- The Children's Foundation
- 725 15th Street, NW., Suite 505
- Washington, DC 20005
- (202) 347-3300
- Child Welfare League of America
- 440 First Street, NW., Suite 310
- Washington, DC 20001-2085
- (202) 638-2952
- http://www.cwla.org
- Family Resource Coalition
- 200 South Michigan Avenue,
- 16th Floor
- Chicago, IL 60604
- (312) 341-0900
- The C. Henry Kempe National Center for the Prevention and Treatment of Child Abuse and Neglect
- 1205 Oneida Street
- Denver, CO 80220
- (303) 321-3963
- http://www.kempecenter.org
- National Association of Child Care Resource and Referral Agencies
- 1319 F Street, NW., Suite 810
- Washington, DC 20004-1106
- (202) 393-5501
- National Black Child Development Institute
- 1023 Fifteenth Street, NW., Suite 600
- Washington, DC 20005
- (202) 387-1281
- http://www.nbcdi.org
- National Center for Children in Poverty
- Columbia University School of Public Health
- Columbia University
- 154 Haven Avenue
- New York, NY 10032
- (212) 927-8793
- (212) 304-7100
- http://cpmcnet.columbia.edu/dept/nccp
- National Center for the Early Childhood Work Force
- 733 15th Street, NW., Suite 800
- Washington, DC 20005
- (202) 737-7700
- National Child Care Information Center
- 301 Maple Avenue West, Suite 602
- Vienna, VA 22180
- (800) 616-2242
- Fax: (800) 716-2242
- http://ericps.ed.uiuc.edu/nccic
- National Head Start Association
- 1651 Prince Street
- Alexandria, VA 22314
- (703) 739-0875
- http://www.nhsa.org
- National Indian Child Care Association
- 279 East 137th Street
- Glenpool, OK 74033
- (918) 756-2112
- National Indian Child Welfare Association
- 3611 S.W. Hood Street, Suite 201
- Portland, OR 97201
- (503) 222-4044
- National Information Center for Children and Youth with Disabilities
- P.O. Box 1492
- Washington, DC 20013-1492
- (800) 695-0285
- http://www.nichcy.org
- National Information Clearinghouse for Infants With Disabilities and Life Threatening Conditions
- University of South Carolina
- Benson Building, First Floor
- Columbia, SC 29208
- (800) 922-9234
- (803) 777-4435
- National Maternal and Child Health Clearinghouse
- 8201 Greensboro Drive, Suite 600
- McLean, VA 22102-3843
- (703) 821-8955
- National Parent Information Network
- ERIC Clearinghouse on Elementary and Early Childhood Education
- University of Illinois at Urbana-Champaign
- Children's Research Center
- 51 Gerty Drive
- Champaign, IL 61820-7469
- (217) 333-1386
- http://www.uiuc.edu
- National Resource Center on Child Abuse and Neglect
- 63 Inverness Drive East
- Englewood, CO 80112-5117
- (800) 227-5242
- National Youth Center Network
- 254 College Street, Suite 501
- New Haven, CT 06510
- (203) 773-0770
- http://www.nycn.org
- Zero to Three: National Center for Infants, Toddlers, and Families
- 734 15th Street, NW., Tenth Floor
- Washington, DC 20005-2101
- (202) 638-1144
- (800) 899-4301 (publications)
- http://www.zerotothree.org

## Foundations

The following are private foundations that provide grants for services and research regarding family-centered interventions. Grant-maker organizations, such as the Foundation Center, can provide information on the wide array of private foundations, corporate grant-makers, grant-making public charities, and community foundations.

- The Carnegie Corporation of New York
- 437 Madison Avenue
- New York, NY 10022
- (212) 371-3200
- http://www.carnegie.org

- The Annie E. Casey Foundation
- 701 St. Paul Street
- Baltimore, MD 21202
- (410) 546-6600
- http://www.aecf.org

- The Ford Foundation
- 320 East 43rd Street
- New York, NY 10017
- (212) 573-5000
- http:/www.forfound.org

- The Foundation Center
- 79 Fifth Avenue/16th Street
- New York, NY 10003-3076
- (212) 620-4230
- http://fdncenter.org

- The William Randolph Hearst Foundations
- 888 Seventh Avenue, 45th Floor
- New York, NY 10106-0057
- (212) 584-5404

- The Robert Wood Johnson Foundation
- Route 1 and College Road East
- P.O. Box 2316
- Princeton, NJ 08543-2316
- (609) 452-8701
- http://www.rwjf.org

- The Henry J. Kaiser Family Foundation
- 2400 Sand Hill Road
- Menlo Park, CA 94025
- (415) 854-9400
- http://www.kff.org

- The W. K. Kellogg Foundation
- One Michigan Avenue East
- Battle Creek, MI 49017-4058
- (616) 968-1611
- http://www.wkkf.org

- The John D. and Catherine T. MacArthur Foundation
- 140 South Dearborn Street, Suite 1100
- Chicago, IL 60603-5285
- (312) 727-8000
- http://www.macfdn.org

- The David and Lucile Packard Foundation
- 300 Second Street, Suite 200
- Los Altos, CA 94022
- (415) 948-7658
- http://www.packfound.org

- The Pew Charitable Trusts
- 2005 Market Street, Suite 1700
- Philadelphia, PA 19103
- (215) 575-9050
- http://www.pewtrusts.com