# Abbreviations and Glossary

## Abbreviations and Acronyms

ACOG | | American College of Obstetricians and Gynecologists
ADHD | | attention deficit hyperactivity disorder
AFDC | | Aid to Families with Dependent Children
AHCPR | | Agency for Health Care Policy and Research
AIDS | | acquired immunodeficiency syndrome
AODs | | alcohol and other drugs
ATP | | Adolescent Transitions program
BET | | bicultural effectiveness training
CAPS | | communication and parenting skills
CDC | | Centers for Disease Control and Prevention
COSSMHO | | National Coalition of Hispanic Health and Human Services Organizations
CSAP | | Center for Substance Abuse Prevention
CSAT | | Center for Substance Abuse Treatment
DHHS | | U.S. Department of Health and Human Services
FAST | | Families and Schools Together
FET | | family effectiveness training
FFT | | functional family therapy
GDVM | | Group Discussion_Oriented Basic Parent Skills Training program
HIV | | human immunodeficiency virus
HPV | | human papilloma virus
IVM | | individually self-administered videotaped modeling (treatment)
IVMC | | IVM treatment plus therapist consultation
LSD | | lysergic acid diethylamide
MDMA | | 3-4-methylenedioxymethamphetamine
MST | | multisystemic therapy
NCHS | | National Center for Health Statistics
NHIS | | National Health Interview Survey
NHSDA | | National Household Survey on Drug Abuse
NIAAA | | National Institute on Alcohol Abuse and Alcoholism
NIDA | | National Institute on Drug Abuse
NPHS | | National Pregnancy and Health Survey
NPN | | National Prevention Network
ONDCP | | Office of National Drug Control Policy
OSAP | | Office for Substance Abuse Prevention (now CSAP)
PCP | | phencyclidine
PDFY | | Preparing for the Drug (Free) Years
PEPS | | Prevention Enhancement Protocols System
PHS | | Public Health Service
PSST | | problem-solving skills training
SAMHSA | | Substance Abuse and Mental Health Services Administration
SFT | | structural family therapy
SSA | | Single State Agency (State Substance Abuse Agency)
STD | | sexually transmitted disease
TIP | | Treatment Improvement Protocol
TOT | | Training of Trainers
YRBSS | | Youth Risk Behavior Surveillance System

## Glossary

Adjustment disorder - : a behavior-related disorder in which a person exhibits clinically significant emotional or behavioral symptoms in response to a psychosocial stressor. Includes distress in excess of expectations or significant impairment in social or academic functioning. See attention deficit hyperactivity disorder, conduct disorder, and oppositional defiant disorder.

Antisocial and other problem behaviors - : can describe behavior-related problems (e.g., poor conduct and impulsiveness), behavior-related disorders (e.g., attention deficit hyperactivity disorder), or both.

Assignment - : the process by which researchers place study subjects in an intervention, control, or comparison group. Experimental design studies randomly assign study subjects to both intervention and control conditions. Quasi-experimental studies nonrandomly assign study subjects to intervention and comparison conditions. Random assignment increases the likelihood that the intervention and control groups are equal or comparable and have similar characteristics.

Attention deficit hyperactivity disorder (ADHD) - : a behavior-related disorder in which there is a persistent pattern of inattention and/or hyperactivity and impulsivity. See adjustment disorder, conduct disorder, and oppositional defiant disorder.

Attrition - : an unplanned reduction in the size of the study sample resulting from participants dropping out of the evaluation, because of relocation, for example.

Behavioral factor - : a certain pattern of conduct that may be associated with substance abuse-related attitudes or behavior. Most prominent in substance abuse prevention efforts are behavioral factors that lead to the perception of substance use or related conditions as functional or appropriate. See environmental factor, personal factor, and sociodemographic factor.

Behavior-related disorder - : a specific behavioral problem that occurs in persistent patterns and characteristic clusters and causes clinically significant impairment. See behavior-related problem.

Behavior-related problem - : a behavioral problem that is isolated or intermittent and is not part of a persistent behavior pattern and that varies in severity and seriousness of its consequences. See behavior-related disorder.

Bias - : the extent to which a measurement, sampling, or analytic method systematically underestimates or overestimates the true value of an attribute. In general, biases are sources of systematic errors that arise from faulty designs, poor data collection procedures, or inadequate analyses. These errors diminish the likelihood that observed outcomes are attributable to the intervention.

Case study - : a method for learning about a complex instance, based on a comprehensive understanding of that instance, obtained by extensive description and analysis of the instance, taken as a whole and in its context.

Community - : a group of individuals who share cultural and social experiences within a common geographic or political jurisdiction.

Community-based approach - : a prevention approach that focuses on the problems or needs of an entire community, including large cities, small towns, schools, work sites, and public places. See individual-centered approach.

Community readiness - : the degree of support for or resistance to identifying substance use and abuse as significant social problems in the community. Stages of community readiness for prevention provide an appropriate framework for understanding prevention readiness at the community or State level. See community tolerance, confirmation/expansion, denial, initiation, institutionalization, preparation, preplanning, professionalization, and vague awareness.

Community tolerance - : is present when community norms actively encourage problematic behavior, which is viewed as socially acceptable. See community readiness.

Comparison group - : in quasi-experimental evaluation design, a group of evaluation participants that is not exposed to the intervention. This term usually implies that participants are not randomly assigned, but have characteristics similar to the intervention group. See Control group.

Conceptual framework - : in this guideline, the philosophical basis for a prevention approach. Specifically, the assumed reasons or hypotheses that explain why the interventions in a specific prevention approach should work.

Conduct disorder - : a behavior-related disorder that has a repetitive and persistent pattern of violating the basic rights of others or major age-appropriate societal norms or rules. The disorder can include aggression to people and animals, destruction of property, deceitfulness or theft, and serious violation of rules. See adjustment disorder, attention deficit hyperactivity disorder, and oppositional defiant disorder.

Confirmation/expansion - : the stage in which existing prevention programs are viewed as effective and authorities support expansion or improvement of the efforts. Data are routinely collected at this stage, and there is a clear understanding of the local problem and the risk factors for the problem. New programs are being planned to reach other community members at this stage. See community readiness.

Construct - : an attribute, usually unobservable, such as educational attainment or socioeconomic status that is represented by an observable measure.

Contextualism - : is a theory that all behavior must be understood within the context of its occurrence. Context is broadly defined to include transactions not only between a person and his or her immediate environment, but also between and among the individual and the domains of family, school, peers, community, and the larger societal or global environment. Contextualism examines adolescent substance abuse within embedded contexts, such as family conflicts "nested" within the context of the family's culture. See developmental pathways model, social development model, and social ecology model.

Control group - : in experimental evaluation design, a group of participants that is essentially similar to the intervention group but is not exposed to the intervention. Participants are designated to be part of either a control or intervention group through random assignment. See comparison group.

Conventional primary prevention - : substance abuse prevention approaches that focus on deterring initial use. See conventional secondary prevention.

Conventional secondary prevention - : psychology-based substance abuse prevention approaches that encourage people to stop. See conventional primary prevention.

Correlational analysis - : a form of relational analysis that assesses the strength and direction of association between variables.

Cross-sectional design - : a research design that involves the collection of data on a sample of the population at a single point in time. When exposure and health status data are collected, measures of associations between them are easily computed. However, because health status and exposure are measured simultaneously, inferences cannot be made that the exposure causes the health status.

Data - : information collected according to a methodology using specific research methods and instruments.

Data analysis - : the process of examining systematically collected information.

Denial - : the stage in which a behavior is not usually approved of according to community norms. At this stage, people are aware that the behavior is a problem but believe that nothing needs to or can be done about the behavior at a local level. See community readiness.

Design - : often referred to as research or study design, this is an outline or plan of the procedures to be followed in scientific experimentation to reach valid conclusions. See experimental design, nonexperimental design, and quasi-experimental design.

Designer drug - : a synthetic analogue of a controlled substance manufactured illegally for the specific purpose of abuse. Designer drugs are created by making minor changes in the molecular structure of substances such as amphetamines.

Developmental pathways model - : a model that argues that the presence of certain risk factors in a child's life, whether individual, familial, or social in nature, can predispose him or her to engage in negative behaviors, which in turn may lead to additional adverse events and circumstances and further counterproductive and disadvantageous interactions. See contextualism, social development model, and social ecology model.

Dual diagnosis - : a term used to describe the phenomenon of coexisting psychiatric and substance abuse disorders.

Effect - : a result, impact, or outcome. In evaluation research, attributing an effect to a program or intervention requires establishing, through comparison, a logical relationship between conditions with and without the program or intervention.

Effectiveness - : the degree to which a prevention approach or intervention achieves specified objectives or outcomes. See efficacy evaluation and effectiveness evaluation.

Effectiveness evaluation - : assesses an intervention under practice conditions - typically, the implementation of an intervention in the field. See effectiveness and efficacy evaluation.

Efficacy evaluation - : used when an intervention is assessed under optimal program conditions - usually a well-funded project conducted by researchers. See effectiveness and effectiveness evaluation.

Environmental factor - : a factor that is external or is perceived to be external to an individual but that may nonetheless affect his or her behavior. A number of these factors are related to the individual's family of origin, while others have to do with social norms and expectations. See behavioral factor, personal factor, and sociodemographic factor.

Experimental design - : a research design that includes random selection of study subjects, an intervention and a control group, random assignment to the groups, and measurements of both groups. Measurements are typically conducted prior to and always after the intervention. The results obtained from these studies typically yield the most interpretable, definitive, and defensible evidence of effectiveness. See design, nonexperimental design, pre-post test, and quasi-experimental design.

External validity - : the extent to which outcomes and findings apply (or can be generalized) to persons, objects, settings, or times other than those that were the subject of the study. See validity.

Family - : parents (or persons serving as parents) and children who are related either through biology or through assignment of guardianship, whether formally (by law) or informally, who are actively involved together in family life - sharing a social network, material and emotional resources, and sources of support.

Family in-home support - : a prevention approach that addresses risk and protective factors by focusing on preserving families through intervention in their home environments. See family therapy and parent and family skills training.

Family support - : a proactive construct that views parenting as a developmentally learned task for all families and affirms that strategies for delivering family services should be rooted in a community support system. See resilience.

Family therapy - : a prevention approach that provides professionally led counseling services to a family for the purpose of decreasing maladaptive family functioning and negative behaviors and increasing skills for healthy family interaction. See family in-home support and parent and family skills training.

Focus group - : a qualitative research method consisting of a structured discussion among a small group of people with shared characteristics. Focus groups are designed to identify perceptions and opinions about a specific issue. They can be used to elicit feedback from target group subjects about prevention strategies.

Formative evaluation - : a process that is concerned with helping the developer of programs or products through the use of empirical research methodology. Also called feedback evaluation.

Fugitive literature - : articles or materials of a scientific or academic nature that are typically unpublished, informally published, or not readily available to the scientific community, such as internal reports and unpublished manuscripts. In this guideline, some practice cases are considered fugitive literature.

Gateway hypothesis - : a hypothesis stating that the use of alcohol and tobacco at an early age is associated with progression to illicit drug use and greater involvement with drugs at older ages.

Heavy drinker - : a person who consumes 2 or more alcoholic beverages per day or 14 or more alcoholic beverages per week.

Incidence - : the number of new cases of a disease or occurrences of an event in a particular period of time, usually expressed as a rate with the number of cases as the numerator and the population at risk as the denominator. Incidence rates are often presented in standard terms, such as the number of new cases per 100,000 population. See prevalence.

Indicated preventive measure - : a preventive measure directed to specific individuals with known, identified risk factors. See preventive measure, selective preventive measure, and universal preventive measure.

Individual-centered approach - : a prevention approach that focuses on the problems and needs of the individual. See community-based approach.

Initiation - : the stage in which a prevention program is under way but still "on trial." Community members often have great enthusiasm for the effort at this stage because obstacles have not yet been encountered. See community readiness.

Institutionalization - : occurs when several programs are supported by local or State governments with established (but not permanent) funding. Although the program is accepted as a routine and valuable practice at this stage, there is little perceived need for change or expansion of the effort. See community readiness.

Instrument - : a device that assists evaluators in collecting data in an organized fashion, such as a standardized survey or interview protocol. See methodology.

Intermediate outcome - : an intervention outcome, such as changes in knowledge, attitudes, or beliefs, that occurs prior to and is assumed to be necessary for changes in an ultimate or long-term outcome, such as prevention of or decreases in substance use and substance-related problems.

Internal validity - : the ability to make inferences about whether the relationship between variables is causal in nature and, if it is, the direction of causality.

Intervention - : a manipulation applied to a group in order to change behavior. In substance abuse prevention, interventions at the individual or environmental level may be used to prevent or lower the rate of substance abuse or substance abuse-related problems.

Intended measurable outcome - : in this guideline, the overall expected consequences and results of the interventions within each prevention approach.

Lesson learned - : in this guideline, a conclusion that can be reached about a specific prevention approach, based on research and practice evidence reviewed to evaluate that prevention approach.

Longitudinal data - : observations collected over a period of time; the sample may or may not be the same each time (sometimes called "time-series data").

Maturation effect - : a change in outcome attributable to participants' growing older, wiser, stronger, more experienced, and the like, solely through the passage of time.

Mean - : the arithmetic average of a set of numeric values.

Methodology - : a procedure for collecting data. See instrument.

Multicomponent program - : a prevention approach that simultaneously uses multiple interventions that target one or more substance abuse problems. Programs that involve coordinated multiple interventions are likely to be more effective in achieving desired goals than single-component programs and programs that involve multiple but uncoordinated interventions. See single-component program.

Multivariate - : an experimental design or correlational analysis consisting of many dependent variables. See variable.

Nonexperimental design - : a type of research design that does not include random assignment or a control group. With such research designs, several factors prevent the attribution of an observed effect to the intervention. See design, experimental design, pre-post test, and quasi-experimental design.

Oppositional defiant disorder - : a behavior-related disorder showing a recurrent pattern of negative, defiant, disobedient, and hostile behavior toward authority figures. Includes some features of conduct disorder, but does not include the persistent pattern of violating the rights of others or major societal norms or rules. See adjustment disorder, attention deficit hyperactivity disorder, and conduct disorder.

Outcome evaluation or summative evaluation - : analyses that focus research questions on assessing the effects of interventions on intended outcomes. See process evaluation and program evaluation.

Parent and family skills training - : a prevention approach in which parents are trained to develop new parenting skills and children are trained to develop prosocial skills. See family in-home support and family therapy.

Personal factor - : a cognitive process, value, personality construct, and sense of psychological well-being inherent to an individual and through which societal and environmental influences are filtered. See behavioral factor, environmental factor, and sociodemographic factor.

Practice evidence - : information obtained from prevention practice cases, which are generally compiled in the form of case studies and often include information about evaluating program implementation and procedures. See research evidence.

Preparation - : the stage in which plans are being made to prevent a problem, leadership is active, funding is being solicited, and program pilot testing may be occurring. See community readiness.

Preplanning - : the stage in which there is a clear recognition that a problem behavior exists locally and that something should be done about it. At this stage, general information on the problem is available and local leaders needed to advance change are identifiable, but no real planning has occurred. See community readiness.

Pre-post test - : in research design, the collection of measurements before and after an intervention to assess its effects. See design, experimental design, nonexperimental design, and quasi-experimental design.

Prevalence - : the number of all new and old cases of a disease or occurrences of an event during a particular period of time, usually expressed as a rate with the number of cases or events as the numerator and the population at risk as the denominator. Prevalence rates are often presented in standard terms, such as the number of cases per 100,000 population. See incidence.

Prevention approach - : a group of prevention activities that broadly share common methods, strategies, assumptions (theories or hypotheses), and outcomes.

Preventive measure - : denotes a cluster of interventions that share similarities with regard to the population groups among which they are optimally used. See indicated preventive measure, selective preventive measure, and universal preventive measure.

Primary prevention - : efforts that seek to decrease the number of new cases of a disorder. See secondary prevention and tertiary prevention.

Probability sampling - : a method for drawing a sample from a population such that all possible samples have a known and specified probability of being drawn.

Process evaluation - : an assessment designed to document and explain the dynamics of a new or continuing prevention program. Broadly, a process evaluation describes what happened as a program was started, implemented, and completed. A process evaluation is by definition descriptive and ongoing. It may be used to evaluate the degree to which prevention program procedures were conducted according to a written program plan. See outcome or summative evaluation and program evaluation.

Professionalization - : the stage in which detailed information has been gathered about the prevalence, risk factors, and etiology of a local problem. At this point, various programs designed to reach general and specific target audiences are under way. Highly trained staff run the program, and community support and involvement is strong. Also at this stage, effective evaluation is conducted to assess and modify programs. See community readiness.

Program evaluation - : the application of scientific research methods to assess program concepts, implementation, and effectiveness. See outcome or summative evaluation and process evaluation.

Promotion model - : enhancing and making the most of people's positive functioning through development and improvement of competencies and capabilities that strengthen people's functioning and their capacity to adapt.

Protective factor - : an influence that inhibits, reduces, or buffers the probability of drug use or abuse, or a transition to a higher level of involvement with drugs. See risk factor.

Qualitative data - : generally constitute contextual information in evaluation studies and usually describe participants and interventions. Often presented as text, the strength of qualitative data is its ability to illuminate evaluation findings derived from quantitative methods. See quantitative data.

Quantitative data - : in evaluation studies, measures that capture changes in targeted outcomes (e.g., substance use) and intervening variables (e.g., attitudes toward use). The strength of quantitative data is the use of these data in testing hypotheses and determining the strength and direction of effects. See qualitative data.

Quasi-experimental design - : a research design that includes intervention and comparison groups and measurements of both groups, but assignment to the intervention and comparison conditions is not done on a random basis. With such research designs, attribution of an observed effect to the intervention is less certain than with experimental designs. See design, experimental design, nonexperimental design, and pre-post test.

Questionnaire - : research instrument that consists of written questions, each with a limited set of possible responses.

Random assignment - : the process through which members of a pool of eligible study participants are assigned to either an intervention group or a control group on a random basis, such as through the use of a table of random numbers.

Reliability - : the extent to which a measurement process produces similar results on repeated observations of the same condition or event.

Reliable measure - : will produce the same result (score) when applied two or more times. See valid measure.

Representative sample - : a segment of a larger body or population that mirrors in composition the characteristics of the larger body or population.

Research - : the systematic effort to discover or confirm facts by scientific methods of observation and experimentation.

Research evidence - : information obtained from research studies conducted to evaluate the effectiveness of an intervention and published in peer-reviewed journals. See practice evidence.

Resilience - : either the capacity to recover from traumatically adverse life events (e.g., the death of a parent, divorce, sexual abuse, homelessness, or a catastrophic event) and other types of adversity so as to achieve eventual restoration or improvement of competent functioning or the capability to withstand chronic stress (e.g., extreme poverty, alcoholic parents, chronic illness, or ongoing domestic or neighborhood violence) and to sustain competent functioning despite ongoing stressful and adverse life conditions. See family support.

Risk factor - : a condition that increases the likelihood of substance abuse. See protective factor.

Secondary prevention - : efforts that seek to lower the rate of established cases. See primary prevention and tertiary prevention.

Selective preventive measure - : a preventive measure directed to subgroups of populations that have higher than average risk for developing a problem or disorder. See indicated preventive measure, preventive measure, and universal preventive measure.

Simple random sample - : in experimental research designs, a sample derived from indiscriminate selection from a pool of eligible participants, such that each member of the population has an equal chance of being selected for the sample. See stratified random sample.

Single-component program - : a prevention approach using a single intervention or strategy to target one or more problems. See multicomponent program.

Social development model - : a model that seeks to explain behaviors, which are themselves risk factors for substance abuse, by specifying the socialization processes (the interaction of developmental mechanisms carried out through relationships with family, school, and peers) that predict such behavior. See developmental pathways model, contextualism, and social ecology model.

Social ecology model - : a model that posits that an adolescent's interactions with social, school, and family environments ultimately influence substance abuse and other antisocial behaviors. This model also emphasizes the importance of increasing opportunities within the social environment for youth to develop social competencies and self-efficacy. See developmental pathways model, contextualism, and social development model.

Sociodemographic factor - : a social trend, influence, or population characteristic that affects substance abuse-related risks, attitudes, or behaviors. Such factors have an indirect but powerful influence because of the limitations of the political, social, economic, and educational systems of society. See behavioral factor, environmental factor, and personal factor.

Statistical significance - : refers to the strength of a particular relationship between variables. A relationship is said to be statistically significant when it occurs so frequently in the data that the relationship's existence is probably not attributable to chance.

Stratified random sample - : in experimental research designs, a sample group derived from indiscriminate selection from different subsegments of a pool of eligible participants (e.g., men and women). See simple random sample.

Substance abuse - : refers to the consumption of psychoactive drugs in such a way to significantly impair an individual's functioning in terms of physical, psychological, or emotional health; interpersonal interactions; or functioning in work, school, or social settings. The use of psychoactive drugs by minors is considered substance abuse.

Tertiary prevention - : efforts that seek to decrease the amount of incapacity associated with an existing condition. See primary prevention and secondary prevention.

Threats to internal validity - : factors other than the intervention that evaluators must consider when a program evaluation is conducted, regardless of the rigor of the evaluation design, that might account for or influence the outcome. These factors diminish the likelihood that an observed outcome is attributable to the intervention.

Time-series design - : a research design that involves an intervention group evaluated at least once prior to the intervention and retested more than once after the intervention. A time-series analysis involves examination of fluctuations in the rates of a condition over a long period in relation to the rise and fall of a possible causative agent.

Universal preventive measure - : a preventive measure directed to a general population or a general subsection of the population not yet identified on the basis of risk factors, but for whom the prevention activity could reduce the likelihood of problems developing. See indicated preventive measure, preventive measure, and selective preventive measure.

Vague awareness - : the stage in which there is a general feeling that a behavior is a local problem that requires attention. However, knowledge about the extent of the problem is sparse, there is little motivation to take action to prevent it, and there is a lack of leadership to address it. See community readiness.

Valid measure - : accurate assessment of what the evaluator wants to measure. See reliable measure.

Validity - : the ability of an instrument to measure what it purports to measure. See external validity.

Variable - : a factor or characteristic of the intervention, participant, or context that may influence or be related to the possibility of achieving intermediate and long-term outcomes. See multivariate.

NOTE: This glossary is based partially on work performed by Westover Consultants, Silver Spring, MD, and the Pacific Institute for Research and Evaluation, Bethesda, MD, under contract with the Center for Substance Abuse Prevention.