# Collateral Areas of Interest

This appendix briefly discusses available knowledge and research for two family-oriented approaches that fall outside the scope of this guideline (see guideline introduction). This information may be helpful for those organizations and communities that would like to develop these family-centered approaches in tandem with the prevention approaches presented in this guideline. The approaches are

- family-centered treatment for adolescents who are already abusing substances (an area that falls outside the definition of prevention used in the guideline), and
- home visiting, an approach widely used for families with children aged 0 to 3 (an area that falls outside the age range for children addressed in this guideline).

A selected bibliography of key literature reviews and well-known intervention studies is included for each area.

## Family-Centered Treatment for Adolescents Who Abuse Substances

Beginning in the 1980s, with strong assistance from the National Institute on Drug Abuse (NIDA), a small stream of studies examined family therapy and family-based interventions that specifically addressed the problem of adolescent substance abuse. These studies moved away from the traditional interpretation of adolescent development, which presented identification with peers following conflict with and rejection of family as frequent and sometimes necessary elements of adolescent development.

Researchers now believe the desired course of adolescent development is a positive interdependence with, rather than a separation from, family as adolescents learn the roles and tasks of adulthood (Liddle & Diamond, 1991; Steinberg, 1990). The family is not just a reactional field on which adolescent development is played out, but a proactive resource and protective factor for successful movement toward adulthood. In particular, families can play a role in protecting the adolescent from succumbing to peer influences to engage in substance abuse (Hauser et al., 1984, 1985; Liddle & Diamond, 1991).

### Trends Within the Research

Several different types of family therapy are addressed in this research. Some therapies focus directly on improving family systems, such as communication, interactional patterns, and parenting behavior and management (Lewis, Piercy, Sprenkle, & Trepper, 1990a; Piercy & Frankel, 1989), whereas others focus on interactions among the adolescent, the family, and the larger contexts of school and community within which the family resides (Liddle & Dakof, 1995a).

Researchers have found that family interventions can engage and retain families and adolescents in treatment. These interventions have also resulted in significant reductions in substance abuse by adolescents. Other outcomes of family therapy interventions include reducing adolescent problem behaviors related to substance abuse while improving adolescent prosocial behavior. However, the evidence for these outcomes is only suggestive. Studies designed to achieve these outcomes are few, and difficulties exist with their research methodologies and consistency of findings (Liddle & Dakof, 1995b; Piercy & Frankel, 1989; Szapocznik et al., 1988).

Finally, recent studies have expanded the focus of research to include all the contexts within which the adolescent and the family exist. This integrated approach draws on the interactions with and influences of the entire ecological environment of the family and substance-abusing adolescent, giving weight to the intra- and interpersonal dimensions of both the adolescent and the family. These studies include the influences of education, child and adult welfare, law enforcement, the courts, and health care (Hawkins, Catalano, & Miller, 1992; Liddle & Dakof, 1995a; Newcomb & Feliz-Ortiz, 1992).

### Areas for Further Research

Although a promising body of research is developing in family-centered treatment of adolescent substance abuse, the number and depth of coverage of these studies are still limited. Many studies have flawed methodologies, such as no comparison group and small numbers of subjects, and do not use terms and definitions that permit cross-comparisons of study findings. This is particularly true of methodologies that establish the level and types of substances used (Liddle & Dakof, 1995b; Joanning, Quinn, Thomas, & Mullen, 1992).

In addition, cost-benefit analyses of different treatment strategies have not been conducted, although it seems obvious that the more comprehensive and integrated a treatment intervention is, the more costs it will incur. It is unclear at this time whether the margin of improvement obtained from a more expensive treatment justifies the cost of carrying it out (Liddle & Dakof, 1995b).

## Home Visiting for Children Aged 0 to 3

Many practitioners are interested in interventions and approaches for families with infants and toddlers or pregnant women. Although the connection with later adolescent substance abuse may be unknown, research and practice recognizes that the time of a child's birth may present a unique opportunity to positively affect the mother's view of herself and her child, as well as the family environment in which the child will be nurtured (Erickson, Korfmacher, & Egeland, 1992). There is also some evidence that the degree to which an infant or toddler attains appropriate social competence, developed through interactions with parents, is an important childhood developmental factor (Hans, Bernstein, & Percensky, 1991).

For practitioners interested in developing prevention interventions for families with children aged 0 to 3 years (i.e., the prenatal period through toddlerhood), this section briefly describes the approach of home visiting - a family-centered approach widely used for very early intervention. This section describes the types of families best served by home visiting, the interventions and strategies home visiting employs, the evidence for various outcomes, and relevant program and evaluation issues.

### Types of Families Served by Home Visiting

The home and immediate family environment are the entire world of an infant, who is totally dependent on the caregiving of parents and is relatively sheltered from wider interaction with those who might recognize problems or needs for extra support. Thus, home visiting is used primarily as an intervention for improving prenatal care; preparing teenage or new parents; assisting parents with special challenges, such as disabled or developmentally delayed children or low-birth-weight or preterm births; and supporting parents who are at high risk for inadequate parenting or child abuse and neglect or who have a number of risk factors associated with low socioeconomic status. Although home visiting could be implemented as a universal preventive measure, researchers generally agree that it is more appropriate as a selective or indicated preventive measure.

### Types of Interventions

Home visiting interventions can address the following special issues of families with infants or families expecting newborns:

- Improving parenting behavior through coaching of enhanced parent-infant interactions or providing parent training (Erickson et al., 1992; Olds & Kitzman, 1993; Patteson & Barnard, 1990).
- Providing formal or informal social support through activities such as liaison with community services, parent support groups, or individually tailored interactions that help families develop specific capacities (Olds & Kitzman, 1993; Roberts & Wasik, 1990).
- Improving the life course development of mothers (very few interventions address needs of fathers) by helping them prepare and find ways to address their aspirations and skills for improving health, education, employment, and family management (Olds & Kitzman, 1993).

Some interventions begin with hospital coaching of parent-child interactions and continue with home visiting, and some only involve one strategy or the other. Some involve frequent home visits over an extended period of months or years, and others involve only a few visits for 3 to 4 months. Some use professionals such as nurses, social workers, or highly trained researchers; others rely on paraprofessionals.

### Outcomes

The general consensus of a number of literature reviews completed between 1988 and 1994 is that there have been modest, short-term positive effects from most types of home visiting interventions, especially for families who are clearly at risk. These positive effects include the following:

- Improvements have been noted with maltreating mothers in child-rearing skills (Wekerle & Wolfe, 1993). However, none of the interventions appears to have decreased maltreatment as documented in Child Protective Service records (Olds & Kitzman, 1993).
- Decreases in the use of the health care system and emergency room service for children from maltreating families are possible collateral evidence of reduction in maltreatment (Olds & Kitzman, 1993).
- Modest short-term child cognitive benefits have been noted when the parent receives and completes instruction in child development or management (Wekerle & Wolfe, 1993).
- Improvements have been noted in parenting premature infants from disadvantaged backgrounds, especially when a hospital-based intervention is combined with home visiting, or when a hospital-based parenting intervention stresses parent involvement in the hospital care of the infant (Zahr, 1994; Patteson and Barnard, 1990).

However, since the literature reviews examined different types of interventions, used varying criteria for including and excluding studies, and exhibited other methodological problems, practitioners should be aware of the following in considering this approach:

- Home visiting does not appear to show much effect with families from universal populations, although there has been some exploration of using the approach on a short-term, low-intensity basis for all families in a nonrisk population (Wekerle & Wolfe, 1993).
- There is still very little evidence that the approach has long-term effectiveness, in part because longitudinal studies have not been conducted beyond 1 or 2 years (Sandall, 1990; Olds & Kitzman, 1993; Wekerle & Wolfe, 1993).
- For home visiting to be a successful intervention, it must be intensive and occur over a significant period of time. Although researchers use different definitions of these elements, they generally agree that the intervention should include several months of weekly visits. Many researchers believe that the decision about intervention intensity and duration must be made in relationship to the circumstances of each family, and intervention could continue for up to 2 years (Wekerle & Wolfe, 1993; Olds & Kitzman, 1993).
- Several researchers document findings in the literature that indicate home visiting programs must also be comprehensive in focus; include parenting, social support, and health interventions; and be staffed by well-trained professionals (Olds & Kitzman, 1993; Heinicke, Beckwith, & Thompson, 1988).
- Cognitive gain of children is a weak and unreliable measure to determine impact of home visiting on infants. It ignores environmental impacts on infants' cognitive and social development, and does not accurately predict future development (Hans et al., 1991). At least one researcher indicates that home visiting must be accompanied by a center-based component to have positive influences on the infant (Ramey, Bryant, & Suarez, 1985).
- Although home visiting has been successfully used with families of developmentally disabled infants, few studies have documented positive results (Olds & Kitzman, 1993).
- Most of the intervention studies have been carried out with White mothers. Few studies have included fathers (Wekerle & Wolfe, 1993) or examined other ethnic groups (Zahr, 1994).

### Program and Evaluation Issues Needing Further Exploration

A number of researchers note that the home visiting approach is like the proverbial "black box," the inside of which still remains somewhat of a mystery. There is a strong need for further research to examine which types of home visiting work for different families, what is the needed duration and intensity of interventions to achieve positive results, what combination and elements of services are needed, and what are the long-term effects.

Evaluations of home visiting programs have been hampered by the same issues as other approaches presented in this guideline - e.g., the use of control or comparison groups that may exclude high-risk families who need services and a failure to examine the dynamics and effects of attrition. Further, in examining the effects of home visiting on families involved in child maltreatment, varying definitions of child abuse and neglect and varying legal requirements for reporting can make research difficult.

A number of researchers observed the need for more process evaluation of interventions, looking at effects related to varying strategies for delivering the intervention and effects related to who delivers the intervention (Wekerle & Wolfe, 1993; Patteson & Barnard, 1990; Olds & Kitzman, 1993).

Because of the extensive number of literature reviews and documented interventions addressing a broad spectrum of populations, the home visiting approach is promising. However, practitioners should review the literature carefully before using this approach to ensure they fully understand what can be accomplished and under what circumstances. They also will have to make a "leap of faith" in promoting the approach as one that can have subsequent positive effects on reducing adolescent substance abuse. The primary linkage, that improving the social competence of infants and toddlers is a required prelude to the development of social competence in older children, although intuitively sensible, has yet to be made.

## References

### Family-Centered Treatment for Adolescents Who Abuse Substances

Hauser, S. T., Liebman, W., Houlihan, J., Powers, S. I., Jacobson, A. M., Noam, G. G., Weiss, B., & Follansbee, D. (1985).Journal of Youth and Adolescence, 14
Hauser, S. T., Powers, S., Noam, G. G., Jacobson, A. M., Weiss, G., & Follansbee, D. J. (1984).Family contextChild Development, 55
Hawkins, J. D., Catalano, R. F., & Miller, J. Y. (1992).Psychological Bulletin, 112
Joanning, H., Quinn, W., Thomas, F., & Mullen, R. (1992).Journal of Marital and Family Therapy, 18
Lewis, R. A., Piercy, F. P., Sprenkle, D. H., & Trepper, T. S. (1990a).Journal of Adolescent Research, 5
Liddle, H. A., & Dakof, G. A. (1995a).Adolescent drug abuse: Clinical assessment and therapeutic interventions
Liddle, H. A., & Dakof, G. A. (1995b).Journal of Marital and Family Therapy, 21
Liddle, H. A., & Diamond, G. (1991).Family Dynamics Addiction Quarterly, 1
Newcomb, M. D., & Feliz-Ortiz, M. (1992).Journal of Personality and Social Psychology, 63
Piercy, F. P., & Frankel, G. R. (1989).Journal of Family Psychology, 3
Steinberg, L. (1990).At the threshold: The developing adolescent.
Szapocznik, J., Perez-Vidal, A., Brickman A. L., Foote, F. H., Santisteban, D., Hervis, O., & Kurtines, W. (1988).Journal of Consulting and Clinical Psychology, 56

### Home Visiting for Children Aged 0 to 3

Erickson, M. F., Korfmacher, J., & Egeland, B. R. (1992).Development and Psychopathology, 4
Hans, S. L., Bernstein, V. J., & Percensky, C. (1991). Evaluation and Program Planning, 14
Heinicke, C. M., Beckwith, L., & Thompson, A. (1988).Infant Mental Health Journal, 9
Olds, D. L., & Kitzman, H. (1993).The Future of Children, 3
Patteson, D. M., & Barnard, K. E. (1990).Infant Mental Health Journal, 11
Ramey, C., Bryant, D., & Suarez, T. (1985).Current topics in human intelligence
Roberts, R. N., & Wasik, B. H. (1990).Journal of Early Intervention, 14
Sandall, S. R. (1990).Topics in Early Childhood Special Education, 10
Wekerle, C., & Wolfe, D. A. (1993).Clinical Psychology Review, 13
Zahr, L. (1994).Maternal Child Nursing Journal, 22

## Additional Sources

### Family-Centered Treatment for Adolescents Who Abuse Subtances

Catalano, R. F., Morrison, D. M., Wells, E. A., Gillmore, M. R., Iritani, B., & Hawkins, J. D. (1992).Journal of Studies on Alcohol, 53
Conger, R. D., Lorenz, F. O., Elder, G. H., Jr., Melby, J. N., Simons, R. L., & Conger, K. J. (1991).Journal of Early Adolescence, 11
Cox, R. B., Jr., & Ray, W. A. (1994).Contemporary Family Therapy, 16
Dishion, T. J., Reid, J. B., & Patterson, G. R. (1988).Journal of Chemical Dependency Treatment, 1
Erikson, E. H. (1968).Identity: Youth and crisis.
Friedman, A. S. (1989).The American Journal of Family Therapy, 17
Friedman, A. S., & Utada, A. (1992).Family Dynamics Addiction Quarterly, 2
Friedman, A. S., Tomko, L. A., & Utada, A. (1991).Family Dynamics Addiction Quarterly, 1
Freud, A. (1958).Psychoanalytic Study of the Child, 13
Glynn, T. J., & Haenlein, M. (1988).Journal of Chemical Dependency and Treatment, 1
Hill, J. P. (1980).Toward adolescence: The middle school years
Johnson, V., & Pandina, R. J. (1991).American Journal of Drug and Alcohol Abuse, 17
Lewis, R. A., Piercy, F. P., Sprenkle, D. H., & Trepper, T. S. (1990b).Family therapy with adolescent substance abusers
Liddle, H. A., & Dakof, G. A. (1994).Multidimensional family therapy of adolescent substance abuse.
Newcomb, M. D., & Bentler, P. M. (1988).Consequences of adolescent drug use: Impact on the lives of young adults.
Santisteban, D. A., Szapocznik, J., Perez-Vidal, A., Kurtines, W. M., Murray, E. J., & LaPirriere, A. (in press).. Journal of Family Psychology
Schmidt, S. E., Liddle, H. A., & Dakof, G. A. (1996).Journal of Family Psychology, 10
Searight, H. R., Manley, C. M., Binder, A. F., Krohn, E., Rogers, B. J., & Russo, J. R. (1991).Contemporary Family Therapy, 13
Simons, R. L., Whitbeck, L. B., Conger, R. D., & Melby, J. N. (1991).. Journal of Early Adolescence, 11
Stanton, M. D., Todd, T. C., & Associates. (1982).The family therapy of drug abuse and addiction.
Szapocznik, J., Kurtines, W. M., Foote, F. H., Perez-Vidal, A., & Hervis, O. (1986).Journal of Consulting and Clinical Psychology, 54
Todd, T. C., & Selekman, M. (1989).Journal of Psychotherapy and the Family, 6

### Home Visiting for Children Aged 0 to 3

Achenbach, R. M., Phares, V., Howell, C. T., Rauth, V. A., & Nurcombe, B. (1990).Child Development, 61
Atkins, M. (1986).Infant Mental Health Journal, 7
Barrera, M. E., Kitching, K. J., Cunningham, C. C., Doucet, D., & Rosenbaum, P. L. (1990).Topics in Early Childhood Special Education, 10
Booth, C. L., Mitchell, S. K., Barnard, K. E., & Spieker, S. J. (1989).Developmental Psychology, 25
Brooks-Gunn, J., Klebanov, P. K., Liaw, F., & Spiker, D. (1993).Child Development, 64
Casto, G., & White, K. (1985).Journal of Children in Contemporary Society, 17
Dudley, M., Gyler, L., Blinkhorn, S., & Barnett, B. (1993).Australian and New Zealand Journal of Psychiatry, 27
Edelstein, S., Kropenske, V., & Howard, J. (1990).Social Work, 35
Field, T. (1982).Early intervention program for infants
Greenberg, R. A., Strecher, V. J., Bauman, K. E., Boat, B. W., Fowler, M. G., Keyes, L. L., Denny, F. W., Chapman, R. S., Stedman, H. C., LaVange, L. M., Glover, L. H., Haley, N. J., & Loda, F. A. (1994).Journal of Behavioral Medicine, 17
Gross, R. T. (1990).Improving the life chances of children at risk
Korner, A. F. (1987).The handbook of infant development
Lally, J. R., Mangione, P. L., & Honig, A. S. (1988).Parent education as early childhood intervention: Emerging directions in theory, research and practice
Lutzker, J. R. (1990).Behavior Modification, 14
Lutzker, S. Z., Braunling-McMorrow, C., Lutzker, J. R., & Eddleman, J. (1987).Journal of Child and Adolescent Psychotherapy, 4
Olds, D. L., Henderson C. R., Jr., Chamberlin, R., & Tatelbaum, R. (1986).. Pediatrics, 78
Olds, D. L., Henderson, C. R., & Kitzman, H. (1994).Pediatrics, 93
Olds, D., Henderson, C. R., Jr., Kitzman, H., & Cole, R. (1995).Pediatrics, 95
Olds, D. L., Henderson, C. R., Jr., Phelps, C., Kitzman, H., & Hanks, C. (1993).Medical Care, 31
Olds, D. L., Henderson, C. R., Jr., & Tatelbaum, R. (1994).Pediatrics, 93
Olds, D. L., Henderson, C. R., Jr., Tatelbaum, R., & Chamberlin, R. (1986).Pediatrics, 77
Olds, D. L., Henderson C. R., Jr., Tatelbaum, R., & Chamberlin, R. (1988).American Journal of Public Health, 78
Olds, D. L., & Kitzman, H. (1990).Pediatrics, 86
Palkovitz, R. (1984).Developmental Psychology, 20
Parker, S., Greer, S., & Zuckerman, B. (1988).Pediatric Clinics of North America, 35
Ramey, C. T., Bryant, D. M., Wasik, B. H., Sparling J. J., Fendt, K. H., & LaVange, L. M. (1992).Pediatrics, 3
Rauh, V. A., Achenbach, R. M., Nurcombe, B., Howell, C. T., & Teti, D. M. (1988).Child Development, 59
Resnick, M. B.: Armstrong, S., & Carter, R. L. (1988).Developmental and Behavioral Pediatrics, 9
Wasik, B. H., Ramey C. T., Bryant, D. M., & Sparling, J. J. (1990).Child Development, 61
Widerstrom, A. H., Mower, B. A., & Sandall, S. R. (1991).At-risk and handicapped newborns and infants: Development, assessment, and intervention.
Wolfe, D. A., & Wekerle, C. (1993).Clinical Psychology Review, 13