# Methodology for Arriving at Recommendations

## Analysis of Research and Practice Evidence

The analysis of research and practice evidence was conducted on two levels. First, each research study and practice case was analyzed on an individual level with regard to design strengths, weaknesses, and potential biases. Second, each group of research articles and/or practice cases was analyzed by each approach.

### Individual-Level Analysis

Each research study and practice case was analyzed with regard to overall summary information, intervention factors, and research/intervention design. Also, practice evidence was analyzed in terms of process evaluation. The format for analyzing research studies and practice cases, the Annotation Shell, is shown in exhibit C-1.

EXHIBIT C-1: Annotation Shell

(Citation) SECTION 1: SUMMARY OVERVIEW HYPOTHESIS CONCEPTUAL FRAMEWORK PURPOSE OBJECTIVES FINDINGS CONCLUSIONS SECTION 2: THE INTERVENTION TYPE OF INTERVENTION DRUGS OF ABUSE ATOD-RELATED BEHAVIORS GENERAL RISK FACTORS TARGET ENVIRONMENT OR POPULATION SOCIAL OR INSTITUTIONAL SYSTEMS INVOLVED STRATEGIES ACTIVITIES SECTION 3: PROCESS EVALUATION NUMBER OF PERSONS OR AGENCIES SERVED SOCIODEMOGRAPHIC INFORMATION AMOUNT OF SERVICE PROVIDED NUMBER OF MATERIALS DISTRIBUTED AND CALLS RECEIVED LIST OF COLLABORATORS WORK PLANS AND PROGRESS REPORTS NEEDS ASSESSMENT TARGET GROUP REPRESENTATION IN PROGRAM FACILITATION OF OBJECTIVES BY ACTIVITIES APPROPRIATENESS OF MATERIALS RECIPIENT PARTICIPATION AS EXPECTED SECTION 4: RESEARCH DESIGN EVALUATION OR STUDY DESIGN MEASUREMENT ANALYSES ASSESSMENT OF EVIDENCE AUTHOR DISCUSSION OF BIAS COMMENTS

Overall summary information included an overview or abstract of the evidence, the stated or assumed hypothesis guiding the intervention, and a description of the conceptual framework, if any. The summary included the purpose or overall rationale for the study and the objectives of the intervention. The findings were described, including primary and secondary study outcomes, and unintended outcomes, if any.

EXHIBIT C-1: Annotation Shell

(Citation) SECTION 1: SUMMARY OVERVIEW

HYPOTHESIS

CONCEPTUAL FRAMEWORK

PURPOSE

OBJECTIVES

FINDINGS

CONCLUSIONS SECTION 2: THE INTERVENTION TYPE OF INTERVENTION

DRUGS OF ABUSE

ALCOHOL-, TOBACCO-, AND OTHER DRUG-RELATED BEHAVIORS

GENERAL RISK FACTORS

TARGET ENVIRONMENT OR POPULATION

SOCIAL OR INSTITUTIONAL SYSTEMS INVOLVED

STRATEGIES

ACTIVITIES SECTION 3: PROCESS EVALUATION NUMBER OF PERSONS OR AGENCIES SERVED

SOCIODEMOGRAPHIC INFORMATION

AMOUNT OF SERVICE PROVIDED

NUMBER OF MATERIALS DISTRIBUTED AND CALLS RECEIVED

LIST OF COLLABORATORS

WORK PLANS AND PROGRESS REPORTS

NEEDS ASSESSMENT

TARGET GROUP REPRESENTATION IN PROGRAM

FACILITATION OF OBJECTIVES BY ACTIVITIES

APPROPRIATENESS OF MATERIALS

RECIPIENT PARTICIPATION AS EXPECTED SECTION 4: RESEARCH DESIGN EVALUATION OR STUDY DESIGN

MEASUREMENT

ANALYSES

ASSESSMENT OF EVIDENCE

AUTHOR DISCUSSION OF BIAS

COMMENTS

A substantial amount of information was collected with regard to the intervention. This included the type of intervention, the drugs of abuse being studied, the drug-related behaviors being studied, individual and environmental risk factors being studied, the target population of the intervention, the social or institutional systems involved, the type of approaches being used in the intervention, and the specific approaches and activities of the intervention.

Evaluation of the research design was comprehensive and included noting the specific research design employed, the specific behaviors or changes being measured, and the statistical analyses used. The process included a comprehensive review of potential biases that could have influenced the outcomes and attribution of effect.

Each prevention practice case was evaluated with regard to process evaluation. This involved addressing the adequacy of the quantitative and qualitative information collected.

### Group-Level Analysis (Overall Level of Evidence)

Once research and practice evidence were analyzed on an individual level, they were grouped according to prevention approach and then analyzed as a group. The goal of this analysis was to determine what conclusions could be drawn about the evidence for a specific prevention approach and to ascertain the strength of the evidence supporting the conclusions.

The strength or level of evidence was categorized as one of the following: strong, medium, suggestive but insufficient evidence, or substantial evidence of ineffectiveness. These levels are summarized in Table C-1.

TABLE C-1: Criteria for Grading Levels of Evidence

Level of Evidence | Criteria
1. Strong | a. Consistent positive results of strong or medium positive effect from a series of studies, including at least three well-executed studies with experimental or quasi-experimental designs; determination of this level is strengthened by evidence from research in which at least two different methodologies were used OR Evidence from two well-executed research studies with experimental or quasi-experimental designs and consistent results from at least three case studies; b. Unambiguous time ordering of intervention and results; c. Existence of a plausible conceptual model, ruling out or controlling for alternative causal paths or explanations
2. Medium | a. Consistent positive results from a series of studies, including at least two well-executed studies with experimental or quasi-experimental designs; determination of this level is strengthened by evidence from research in which at least two different methodologies were used OR At least one well-executed study and three case studies showing statistically significant or qualitatively clear effects; b. Unambiguous time ordering of intervention and results, when measured; c. Existence of a plausible conceptual model, whether or not competing explanations have been ruled out
3. Suggestive but insufficient evidence | a. Based on plausible conceptual model or previous research; b. Rigorous evaluation studies or appropriate intervention programs are in process; c. Minimal available evidence linking intervention being tested to positive effect
4. Substantial evidence of ineffectiveness | The absence of a statistically significant effect or evidence of a statistically significant negative effect in a majority of well-executed studies, including at least two quantitative studies with sample sizes sufficient to test for the significance of the effect

### Criteria for Grading Levels of Evidence

The criteria for strong level of evidence included consistent results of strong or medium effect from a series of studies, including at least three well-executed studies with experimental or quasi-experimental designs. Alternatively, there could be two well-executed research studies with experimental or quasi-experimental designs and consistent results from at least three case studies.

Either way, there should have been the use of at least two different methodologies, unambiguous time ordering of intervention and results, and a plausible conceptual model ruling out or controlling for alternative causal paths or explanations.

The criteria for medium level of evidence included consistent positive results from a series of studies, including at least two well-executed studies with experimental or quasi-experimental designs. Alternatively, there could be at least one well-executed study and three prevention case studies showing statistically significant or qualitatively clear effects.

Either way, there should have been the use of at least two different methodologies; unambiguous time ordering of intervention and results when so measured; and a plausible conceptual model, whether or not competing explanations had been ruled out.

A third category, called suggestive but insufficient evidence, was used to describe research and/or practice evidence based on a plausible conceptual model or on previous research and demonstrated in rigorous evaluation studies or appropriate intervention programs currently in process. One of two conditions typically prompted this categorization. In the first condition, the evidence, although limited, appeared to support a conclusion, but additional data were needed to fully support this conclusion. This condition often applied to areas in which there have been little study, such as those that are impractical to research or new areas of study. A second condition involved equivocal results. In this condition, a specific conclusion was supported in some studies but not in others.

The three categories described above provide a way to arrange research and practice evidence for which there are varying degrees of confirmation of positive effect. A fourth category called substantial evidence of ineffectiveness describes research and practice evidence demonstrating that a prevention approach is not effective. The criteria for inclusion in this category was the absence of a statistically significant effect or a statistically significant effect in the unexpected direction in a majority of well-executed studies, including at least two quantitative studies with sample sizes sufficient to test for the significance of the effect.

## Rules of Evidence Abstract

The Center for Substance Abuse Prevention (CSAP) created the Prevention Enhancement Protocols System (PEPS) as part of its initiative to support and strengthen the prevention systems in the States and territories. PEPS aims to compile, analyze, and synthesize existing knowledge on specific topics in the prevention of alcohol, tobacco, and illicit drug-related problems. These topics are considered by experts to have major consequences for the field of substance abuse prevention. Further, there is substantial knowledge available on these chosen topics to synthesize in the form of specific guidelines. The PEPS guidelines are designed to assist States, practitioners, and community-based organizations in program planning, allocating resources, and choosing program options appropriate for the needs of their target populations.

Several previous attempts have been made by CSAP - as well as by other Federal, State, and community-based organizations - to provide guidance to the field. PEPS, however, is the first known systematic guideline development process in the field of alcohol, tobacco, and illicit drug problem prevention. Although the accumulated knowledge and practice in the field of prevention in general, and alcohol, tobacco, and illicit drug problem prevention in particular, present special challenges for developing systematic guidelines, PEPS has benefited from earlier efforts by Federal agencies and professional medical societies in developing guidelines for medical practice.

Early in the PEPS program, CSAP was faced with the choice of developing guidelines through primary reliance on professional consensus or explicit evidence. Under the former methodology, a group of well-known consultants is assembled and asked to develop the guidelines based on their knowledge of the literature and their own experience. Under the latter methodology, published and unpublished evidence on a given guideline topic are researched according to a defined protocol and analyzed for validity. The cumulative evidence is then synthesized and its strength assessed according to clearly laid out rules for synthesis and development of recommendations.

Although the evidence-based approach demanded greater effort and investment of resources, CSAP decided that developing the guidelines on the basis of explicit evidence would provide more valid tools for prevention planners and practitioners and would also further the quest for new knowledge in areas where evidence is not strong or is lacking. To this end, the PEPS Planning Manual was developed to instruct participants in the various stages of the development of guidelines under the PEPS program.

The Planning Manual contains the rules of evidence document, which provides criteria for assessing the strength of available evidence for the effectiveness of alcohol, tobacco, and illicit drug problem prevention interventions, measures, and programs. These criteria are applied by the PEPS team to determine the level of evidence available for a particular intervention. The level of evidence indicates the level of confidence that there is a causal relationship between a prevention intervention and a change in the outcome(s) of interest; thus, it indicates the overall effectiveness of the prevention activity.

The Planning Manual also presents definitions of research and practice evidence. These definitions are followed by summaries of methodological and design issues to be considered in assessing individual studies and programs; criteria for determining the strength of evidence for the effectiveness of an intervention, combining research and practice evidence; and procedures for specifying the conditions under which the relationship between a particular intervention and outcome operates. The strength or level of evidence for an intervention and the conditions under which this level operates serve as recommendations regarding this intervention to the field.

The assessment criteria and levels of evidence discussed in this appendix have been developed for use in the evaluation of existing research and practice evidence. These criteria were not intended for use in designing interventions or research studies or for developing policy.

## Assessment of the Evidence

### Biases

Biases are sources of systematic errors that arise from faulty designs, poor data collection procedures, or inadequate analyses. These errors diminish the likelihood that observed outcomes are attributable to the intervention. Biases are inherently present in many nonexperimental observational studies but are of special significance in case-control studies. Experimental and quasi-experimental study designs control for many of these biases.

- Selection bias - A selection bias results when individuals knowingly or unknowingly are selectively included or excluded from the case or the control group. Systematic and disproportionate frequency of important variables in the case or control groups may result in a spurious measure of association. Epidemiological studies are laden with problems of selection bias. Potential problems include selective admission, selective nonparticipation, selective survival, and selective detection. An example of selection bias is a comparison group that is not equivalent to the intervention group because of demographic, psychosocial, or behavioral characteristics. Because case-control studies are especially susceptible to selection bias, multiple control groups should be chosen instead of only one, and at least one of the groups should come from the same source of care as the case group.
- Measurement bias - Measurement bias may result when collected information on either the exposure variable or the health state is unreliable or invalid. Historical data obtained by interviewing subjects without appropriate validation against recorded data or interviews with collateral sources are especially susceptible to one form of measurement bias called recall bias. Another common source of measurement bias is the use of scales that have not been tested for reliability or validity. Ways to control for information bias include using only accurately recorded data, validating interview information, blinding the investigator to the identity of the case or control subjects, and adhering to an explicit and standardized method of data collection.
- Confounding bias - An observed effect between intervention A and outcome B may be attributable to a third factor, C, which is related to both A and B. In other words, whereas the relationship between A and B may be weak or nonexistent, the explanatory relationship is between C and B. Thus, an effect can be detected that is attributable to a confounding factor, not the intervention. Age, ethnicity, sex, and socioeconomic status are important confounders. Ways to control for confounding bias include matching techniques in the design stage and using stratification and multivariate analysis during the analysis stage.
- Attrition - Attrition that is nonrandom or excessive (defined as a dropout rate of 10 percent or more) in the intervention or the control group can introduce a bias in the outcome data. A differential drop-out rate between the groups may also introduce a bias in outcome data.

### Internal Validity

Internal validity is the extent to which an observed effect can be attributed to an intervention. Threats to internal validity are particularly germane to intervention studies, although policy and nonintervention studies may be susceptible to threats of statistical power, history, and unit of assignment.

The overall question regarding internal validity is whether the intervention or some other factors produced the observed effect.

- Equivalence - For studies that have an intervention and a control or comparison group, comparisons between the two groups are most valid when they consist of subjects that are essentially similar at the beginning of the study. When this is not true, outcomes observed may not be attributable to the intervention because the groups were already different in some way.
- Statistical power - There should be an adequate number of participants in each of the intervention and control or comparison groups in order to detect statistically significant differences in outcomes. A rough guide for the minimum number of participants in each group is 30. Fewer than 30 participants per group generally do not yield adequate statistical power. Regardless of the total number in a group, the groups should be about the same size.
- Intervention contamination - It is important for the control or comparison groups to remain unaffected by the intervention. When they are affected, the control or comparison groups may change in similar ways to the intervention group, thereby obscuring the effects of the intervention. For example, intervention contamination could result if the control or comparison group received any information about the intervention that would affect the outcome.
- Randomization or blinding of observers - When research study staff know the status of an individual or a group (intervention or control status), they may change their own behavior in ways that can affect study outcomes. To minimize this bias, the observers can be either blinded to the conditions or randomized to measure either intervention or comparison groups.
- Fidelity - The intervention should be delivered consistently during the intervention period. Ideally, the researchers will have used a written protocol for intervention delivery and will have documented a standard delivery to all study participants.
- Unit of analysis and assignment - Participants in a prevention program can be assigned to a control or intervention condition on an individual basis or on a collective basis, such as by classroom or community. Similarly, analysis of a research study can be done on an individual or a collective basis. The unit of assignment and the unit of analysis should be the same when researchers analyze the effects of the intervention.
- History - Significant and unplanned national, State, local, or internal organizational events or exposure occurring at the program site during the evaluation study period can result in a change by participants. In studies with a time-series design, history is the principal threat to internal validity. For these designs, it is particularly important to assess the plausibility of effects from factors such as weather, seasonality, shifts in personnel, changes in resources, or the enactment of a new law or policy.
- Program or participant maturation - Natural, biological, social, behavioral, or administrative changes that occurred among participants or staff members during the study period may result in program or participant maturation and could partially account for the results obtained. Such changes can include growing older, becoming more skilled, or staff becoming more effective and efficient in program delivery.
- Testing or observation - Participants' behavior regarding study outcomes can change when they are frequently tested or observed. Measurements that occur at close points in time can also change the behavior and responses of study participants. The behavior of study subjects can change because, for example, they were taking a test or being interviewed or observed.
- Statistical regression - Statistical regression can result when an intervention or comparison group is selected on the basis of an unusually high or low level of a characteristic that may change naturally in subsequent measurements. The extent to which regression compromises results can be determined by examining the comparability of people who participate and those who do not. Studies employing a one-group pretest and posttest design or a nonequivalent control group are poor at controlling for statistical regression.
- Interactive effects - Any combination of the preceding factors constitutes interactive effects.

### External Validity

The focus of external validity is generalizability, that is, the extent to which an observed effect that is attributable to an intervention can be expected in other settings and populations with similar or different characteristics.

- Contextual factors - In the alcohol, tobacco, and illicit drug prevention field, contextual factors relate to the degree to which a community is ready to prevent alcohol, tobacco, and illicit drug use. Indicators of community readiness include norms, favorable attitudes, and restrictive policies. Studies of communities with a high degree of readiness for prevention may not be generalizable to all communities. For example, the ability to establish outdoor tobacco advertising restrictions would differ between California and North Carolina.
- Generalizability - Factors unique to a study make it difficult to generalize the findings to similar or general populations. For instance, a school-based intervention in a primarily urban setting for African-American students may not be generalizable to a suburban school setting with primarily refugee students.

## Bibliography

Campbell, D., & Stanley, J. (1996).Experimental and quasi-experimental designs for research
Depression Guideline Panel. (1993, April).Depression in primary care:Diagnosis and detection
Green, L. W., & Kreuter, M. W. (1991).Health promotion planning: An educational and environmental approach.
Hayward, R. S., Steinberg, E. P., Ford, D. E., Roizen, M. F., & Roach, K. W. (1991).Annals of Internal Medicine, 114
Hill, A. B. (1971).Principles of medical statistics
Kleinbaum, D. G., Kupper, L. L., & Morgenstern, H. (1982).Epidemiological research: Principles and quantitative methods
Koepsell, T. D., Wagner, E. H., Cheadle, A. C., Patrick, D. L., Martin, D. C., Diehr, P. H., Perrin, E. B., Kristal, A. R., Allan-Andrilla, C. H., & Dey, L. J. (1992).Annual Review of Public Health, 13
Windsor, R. A., Baranowski, T., Clark, N., & Cutter, G. (1984).Evaluation of health promotion and education programs