# Research and Practice Search Protocols

## Protocol for Identifying Research Evidence

1. Through revisions of the prospectus and meetings of the Federal Resource Panel, the topics to be covered in this guideline were narrowed and keywords identified.
2. The first set of searches, conducted in PsycLIT, MEDLINE, Reader's Guide Abstracts, and Sociofile databases, located literature regarding the following:
  a. The combination of keywords,
    - children, family, or parents; and
    - substance or drug use or abuse; and
    - prevention.
  b. Names of proposed Expert Panelists.
  c. Deviant behavior and adolescents.
  d. Ecology of substance abuse.
3. The PEPS Team Leader selected articles for retrieval based on the abstracts obtained in the initial database search. Once retrieved, the articles were added to an annotated bibliography, which was updated frequently with new resources throughout the search process.
4. Several recently published books from local health libraries were reviewed and the appropriate chapters retrieved.
5. Bibliographies from the panel chair's research and that of other panel members were reviewed by the Team Leader. Promising articles from these bibliographies, as well as articles directly recommended by the panel chair, were retrieved.
6. Most of the abstracts from Reader's Guide Abstracts, MEDLINE, and Sociofile did not yield promising or new information during the first searches. Therefore, a second group of searches was performed only on PsycLIT, as follows:
  a. Names of family-focused prevention researchers.
  b. Resilient children, youth, and adolescents.
  c. High-risk children, youth, and adolescents.
  d. Protective factors.
  e. Family support.
  f. Family preservation.
7. A search of the Family Resources Database was performed on Dialog to locate publications after 1987 regarding
  a. family, parent, adolescent, or child; and
  b. alcohol, tobacco, substance, or drug use or abuse; and
  c. prevention.
8. After a meeting with the panel chair and the PEPS Team Leader, PEPS staff completed literature searches in PsycLIT and Sociofile, using the following keywords:
  a. Home-based therapy and intervention.
  b. Family therapy.
  c. Family skills training.
  d. Parent education, training, aid, and support.
  Because these keywords sometimes yielded an unwieldy number of nonrelevant articles, some of these searches were made more specific by the use of other keywords, such as substance abuse, drugs, youth, and children.
9. During the next few searches, as the PEPS Team Leader and the panel chair narrowed the scope of the guideline, articles were identified by using the following methods:
  a. Searching names of authors who published promising studies already retrieved by PEPS staff.
  b. Retrieving articles cited in the bibliographies of studies written by the panelists and of other promising studies already retrieved by staff.
  c. Searching approach-specific keywords suggested by the panel chair.
10. After the Expert Panel's first meeting, during which the prevention approaches to be described in the guideline were defined, PEPS staff conducted a search by the names of approaches that had not yet been searched. In addition, the panel provided PEPS staff with a wealth of research resources to be retrieved within each approach and procedures for assessing fugitive literature.
11. In addition, several panelists submitted approach-specific lists of resources, which were reviewed by the PEPS Team Leader.
12. A variety of similar searches were conducted to gather information on conduct disorders and on behavior problems of adolescents.
13. All of the retrieved articles were reviewed. Those meeting the criteria of relevancy to the topic and application of an intervention to prevent alcohol, tobacco, and illicit drug use among children and adolescents were selected for annotation. Criteria included the following:
  a. The child, rather than the family, was the target of prevention efforts.
  b. The treatment group included more than 10 subjects.
  c. The intervention study had relevant outcome measures.
  d. The target child was at least 4 years old.
14. The articles that met the criteria were annotated and organized by approach.
15. The PEPS manager, the PEPS Team Leader, the panel chair, and finally, the Expert Panel for this guide reviewed the approaches and articles and selected those to be included.
16. Six of the approaches that were initially considered were eliminated from presentation in chapter 3 because the available research on them was insufficient. Research was considered sufficient for those approaches that had been examined in at least three intervention research studies. Therefore, approaches examined only in practice literature were eliminated. The six eliminated approaches were
  a. parent leadership,
  b. parent peer support,
  c. parent involvement in youth prevention programs,
  d. parent-child activities,
  e. parent education, and
  f. family support.

## Results

- More than 700 articles were retrieved.
- A total of 52 research studies, represented by 64 articles, were included in the guideline.

## Protocol for Soliciting Practice Evidence

1. Single State and Territorial Agency (SSA) directors, State National Prevention Network (NPN) designees, and Federal Resource Panel members were each sent a letter requesting information on family-based programs that serve as examples of how to (and how not to) prevent alcohol, tobacco, and illicit drug-related problems within the context of the family as a social and cultural unit. The letters included background information on the PEPS program, a short nomination form requesting contact information concerning practice projects (see Practice Evidence Nomination Form at the end of this appendix), and a longer nomination form requesting specific project information.
2. Other groups who received requests for nomination included the following:
  a. The Robert Wood Johnson Foundation.
  b. American Humane Association.
  c. Child Welfare League of America.
  d. National Resource Center for Family-Centered Practice.
  e. Center for Family Research.
  f. Center for the Improvement of Child Caring.
  g. Parenting: A Skills Training Program, Pennsylvania State University.
  h. COSSMHO (National Coalition for Hispanic Health and Human Services).
  i. Ounce of Prevention.
  j. Family Resource Coalition.
  k. National Black Child Development Institute.
  l. The Carnegie Foundation.
3. Followup phone calls were made to the State directors requesting the return of the nomination forms. Nominations were received from 31 States.
4. Followup faxes requesting project information were sent to all nominated contact persons.
5. All nominated projects were reviewed. Those meeting the following criteria were selected for annotation:
  a. Clearly stated objectives.
  b. Definition and description of the intervention.
  c. Process evaluation documentation.
  d. Outcome evaluation information.
  e. Adequate documentation to annotate the project.
6. Those projects that met the criteria were annotated and organized by approach.
7. The annotations were reviewed by the Family Expert Panel Subgroup for inclusion in the guideline.

### Results

- A total of 108 programs were reviewed.
- Nine programs met the criteria and were included in the guideline.

### Practice Evidence Nomination Form

CRITERIA FOR PEPS PROGRAM REVIEW/TRIAGE (Please check all questions that apply) | Yes | No | Do Not Know
Planning/Rationale Was a community/broup needs assessment conducted? Were specific research findings/concepts used as a basis for program planning?
Program Design Are objectives clearly documented? Are selected strategies/activities explicitly related to stated objectives?
Documentation Is there a system in place for documenting implementation and operations? Documenting outcomes? Are progress reports, program assessments, and evaluation results available? Are training materials and/or operations manuals available?
Evaluation/Outcomes If program has ended: Did the program achieve desired outcomes or related positive outcomes? If program has not ended: Are there specific plans to assess outcomes?
Replication Does the program show promise for replication? Has this program been replicated?