# PEPS Participants

PEPS Family Expert Panel
- Karol L. Kumpfer, Ph.D., Chair
- Department of Health Education
- University of Utah
- Salt Lake City, UT
- José Szapocznik, Ph.D., Co-chair
- Center for Family Studies
- Department of Psychiatry
- University of Miami
- Miami, FL
- Richard Catalano, Ph.D.
- Social Development Research Group
- University of Washington
- Seattle, WA
- Richard R. Clayton, Ph.D.
- Center for Prevention Research
- University of Kentucky
- Lexington, KY
- Howard A. Liddle, Ed.D.
- Center for Family Studies
- Department of Psychiatry
- University of Miami
- Miami, FL
- Robert McMahon, Ph.D.
- Department of Psychology
- University of Washington
- Seattle, WA
- Joyce Millman
- Northern Illinois Council on Alcoholism and Substance Abuse
- Round Lake, IL
- Maria Elena V. Orrego, M.A.
- Family Resource Coalition
- Washington, DC
- Nila Rinehart
- State of Alaska Children's Cabinet
- Juneau, AK
- Iris Smith
- Department of Children and Youth Services
- Office of Program Development and Evaluation
- Atlanta, GA
- Richard Spoth, Ph.D.
- The Center for Family Research in Rural Mental Health
- Ames, IA
- Marilyn Steele, Ph.D.
- Consulting and Clinical Services
- Los Angeles, CA

PEPS Planning Group
- Richard R. Clayton, Ph.D., Chair
- Center for Prevention Research
- University of Kentucky
- Lexington, KY
- Thomas E. Backer, Ph.D.
- Human Interaction Research Institute
- Los Angeles, CA
- Leonard G. Epstein, M.S.W.
- Division of Community Prevention and Training
- Center for Substance Abuse Prevention
- Rockville, MD
- Bettye Ward Fletcher, Ph.D.
- Research and Development
- Jackson State University
- Jackson, MS
- Jean L. Forster, M.D., M.P.H.
- Division of Epidemiology
- University of Minnesota School of Public Health
- Minneapolis, MN
- William M. Harvey, Ph.D.
- Missouri Institute of Public Health
- St. Louis, MO
- Ralph W. Hingson, Sc.D.
- Social and Behavioral Sciences Department
- Boston University
- Boston, MA
- Jan Howard, Ph.D.
- Prevention Research Branch
- National Institute on Alcohol Abuse and Alcoholism
- Rockville, MD
- Ford H. Kuramoto, D.S.W.
- Los Angeles Office of National Asian Pacific American Families Against Substance Abuse, Inc.
- Ford H. Kuramoto and Associates
- Monterey Park, CA
- Jeffrey N. Kushner, M.A.
- Assistant Director
- Oregon Department of Human Resources
- Salem, OR
- Andrea L. Mitchell, M.L.S.
- Alcohol Research Group
- Western Consortium for Public Health
- Berkeley, CA
- Abdin Noboa, Ph.D.
- Innovative Consultants International
- Columbus, OH
- Pamela Petersen-Baston, M.P.A., C.A.P.
- Independent Consultant
- Key West, FL
- Eva L. Petoskey, M.A.
- First American Prevention Center
- Suttons Bay, MI
- Robert I. Reynolds, M.A.
- National Center for the Advancement of Prevention
- Rockville, MD
- Robert G. Robinson, Ph.D.
- National Center for Chronic Disease Prevention and Health Promotion
- Centers for Disease Control and Prevention
- Atlanta, GA
- Robin G. W. Room, Ph.D.
- The Addiction Research Foundation
- Toronto, Ontario
- Zili Sloboda, Sc.D.
- Division of Epidemiology and Prevention Research
- National Institute on Drug Abuse
- Rockville, MD
- José Szapocznik, Ph.D.
- Center for Family Studies
- Department of Psychiatry
- University of Miami School of Medicine
- Miami, FL
- Ralph E. Tarter, Ph.D., M.P.A.
- Western Psychiatric Institute and Clinic
- University of Pittsburgh School of Medicine
- Pittsburgh, PA
- Mel Tremper, Ph.D.
- National Center for the Advancement of Prevention
- Rockville, MD
- Friedner D. Wittman, Ph.D., M.Arch.
- CLEW Associates
- Berkeley, CA

Ex Officio Member
- Prakash L. Grover, Ph.D., M.P.H.
- PEPS Program Director
- Senior Science Advisor
- Division of State and Community Systems Development
- Center for Substance Abuse Prevention
- Rockville, MD

PEPS Family Federal Resource Panel
- Barbara Bennetts
- Administration for Native Americans
- U.S. Department of Health and Human Services
- Washington, DC
- Johanna G. Clevenger, M.D.
- Alcoholism and Substance Abuse Branch
- Indian Health Service
- Rockville, MD
- Emily Cook
- National Center on Child Abuse and Neglect
- Washington, DC
- Shirley Haile-Howard
- Children's Bureau
- Administration on Children, Youth, and Families
- Washington, DC
- Joan Hurley
- Department of Justice
- Juvenile Justice and Delinquency Prevention
- Washington, DC
- Norman Krasnegor
- Human Learning and Behavior Branch National Institute of Child Health and Human Development
- Bethesda, MD
- Terry Lewis
- Family and Youth Services
- Administration on Children, Youth, and Families
- Washington, DC
- Donna Marie Marlow
- Office of Elementary and Secondary Education
- U.S. Department of Education
- Washington, DC
- Gloria Mora
- Bureau of Indian Affairs
- Office of Alcohol and Substance Abuse Prevention
- Washington, DC
- Phyllis Nophlin
- Head Start
- U.S. Department of Health and Human Services
- Washington, DC
- Barbara Rosengard
- Office of Population Affairs
- U.S. Department of Health and Human Services
- Rockville, MD

NCAP Staff
- Deborah Fisher
- National Center for the Advancement of Prevention
- Rockville, MD

CSAP Representatives
- Prakash L. Grover, Ph.D., M.P.H.
- Division of State and Community Systems Development
- Center for Substance Abuse Prevention
- Rockville, MD
- Gale A. Held
- Division of State and Community Systems Development
- Center for Substance Abuse Prevention
- Rockville, MD
- Theodore Weiss
- Division of State and Community Systems Development
- Center for Substance Abuse Prevention
- Rockville, MD
- Clarese Holden
- Division of State and Community Systems Development
- CSAP Prevention Technical Assistance and Training to the States
- Rockville, MD
- Lee Wilson
- Division of State and Community Systems Development
- CSAP Prevention Technical Assistance and Training to the States
- Rockville, MD

Birch & Davis Associates, Inc., Staff
- Jeffery A. Hunter, M.B.A., M.P.H.
- Principal in Charge
- CSAP Prevention Technical Assistance and Training to the States
- Stephen H. Martin
- Project Director
- CSAP Prevention Technical Assistance and Training to the States
- Robert M. Bozzo, M.A. Mary V. Davis, Ph.D. (4/94 through 11/96)
- PEPS Project Manager
- Mim J. Landry
- Medical Writer and Research Associate
- Betsy Earp Chip H. Moore (through 3/98)Deborah J. Shuman (3/95 through 10/96)Jennie E. Heard (2/92 through 4/95)
- Managing Editors
- Susan Weber, M.A., M.P.A.
- PEPS Content Analyst
- Christine H. Kelley Cheryl Droffner Elizabeth B. Hayes (12/93 through 12/95)Sharon Ziegler (11/93 through 9/95)
- PEPS Research and Editorial Assistants