# About This Guideline

The Prevention Enhancement Protocols System (PEPS) is a systematic and analytical process that synthesizes a body of knowledge on specific prevention topics. It was created by the Division of State and Community Systems Development of CSAP/SAMHSA primarily to support and strengthen the efforts of State and Territorial agencies responsible for substance abuse prevention activities. The PEPS program is CSAP's response to the field's need to know "what works," and represents an acceptance of the responsibility for leading the field with current information supported by the best scientific knowledge available.

This third guideline in the PEPS series summarizes state-of-the-art approaches and interventions designed to strengthen the role of communities in preventing substance abuse and other alcohol-related problems. This topic was chosen in response to the field's expressed need for direction and in recognition of the important role of the environment as the first line of defense against the dangerous, insidious, and addictive consequences of alcohol use.

Those who have seen one or both of the earlier guidelines in the PEPS series will readily identify the many changes that have been made to make its contents more readable while enhancing the attractiveness of the document. In addition, substantive changes have been made in the placement of material within chapters to provide early on what the readers look for first. Details supporting these earlier sections are placed so that the readers can refer to them as much or as little as they need.

## The PEPS Development Process

The development of a PEPS guideline begins with the deliberations of a Planning Group comprising nationally known researchers and practitioners in the field of substance abuse prevention. With input from their colleagues in the field, these experts identify a topic area that meets established criteria for developing a guideline. A Federal Resource Panel (FRP) with representatives from appropriate Federal agencies then convenes to discuss the proposed content of the guideline. The FRP, taking into consideration recommendations from CSAP and the PEPS Planning Group, identifies those experts in the field best suited to serve on an Expert Panel for the chosen topic.

Once formulated, the Expert Panel meets to determine the scope of the problem to be addressed in the guideline. The PEPS staff conducts exhaustive searches for relevant research and practice information, guided by the knowledge of the Expert Panel and its Chair. The studies and practice cases found are extensively analyzed. The findings are compiled and presented in draft form grouped by the type of the prevention approaches used.

A subpanel of the Expert Panel members then meets to apply the PEPS Rules of Evidence (described later in this section) to formulate summary judgments on the quality of the research and practice evidence by approach and to develop recommendations for the prevention field. This draft is reviewed by the full Expert Panel. A revised version of the guideline, including the revisions of the Expert Panel, is distributed for an extensive review by the field. The critiques and analyses received are used to further refine and enhance the accuracy, readability, and presentation of the guideline.

## PEPS Series Goals

The primary goal of PEPS is to develop a systematic and consistent process for improvement of substance abuse prevention practice and research. Its objectives are to

- Synthesize research and practice evidence on selected topics
- Present recommendations for effective substance abuse prevention strategies in versions suitable for several target audiences
- Ensure that PEPS products receive optimal dissemination among target audiences
- Monitor the usefulness and relevance of PEPS products

Although lessons from available science are distilled and specific recommendations are made, this guideline is not a "how-to" handbook, nor is it a prescriptive prevention planning guide. Broad audiences for PEPS products include State prevention agencies, other Federal and State authorities, and community-based organizations addressing the problems of substance abuse or serving high-risk populations. Specific targeted users of the PEPS guidelines include policy analysts and decisionmakers, who need sound data to justify funding for prevention planning; State agency and community-based administrators and managers, who will find the series useful in allocating resources and planning programs; researchers, who will receive guidance on the need for future studies; and practitioners, who will find recommendations for programming options that are most appropriate for the populations they serve.

## The Scope of This Guideline

Preventing Problems Related to Alcohol Availability: Environmental Approaches focuses on research and practice evidence for a select number of approaches to the prevention of alcohol availability-related problems. The criteria used for inclusion of studies as "evidence" in this guideline (described in appendix A) excluded some research and practice studies. However, there was sufficient documentation to evaluate the following six prevention approaches:

1. Preventing Availability to Underage Youth
2. Raising Alcohol Taxes and Prices
3. Responsible Beverage Service
4. Changing the Conditions of Availability
5. Changing Hours and Days of Sale
6. Community-Based Prevention Approach

The information included in this guideline was used to develop two additional publications: a practitioners' guide and a guide for communities. The practitioners' guide summarizes much of the information in this reference guide and highlights practical information that is most useful to those directly involved in planning and implementing prevention programs. The community guide provides both a brief overview of substance abuse problems and courses of action for concerned citizens and provides tips for becoming involved in preventing alcohol availability problems.

## Levels of Evidence

At the heart of the guideline development process are several concepts concerning the weight of the evidence that makes research or practice information strong enough to serve as the basis for recommendations. As these concepts are essential to understanding the rigorous process used in developing this guideline, they are explained in detail in this introductory section.

The term research evidence refers to the research-based body of knowledge existing for a specific prevention approach. This information is gained from scientific investigations that range in design rigor from experimental to quasi-experimental to nonexperimental. The term practice evidence describes information gained from prevention practice cases, which is generally presented in the form of well-designed and -executed case studies that include process evaluation information on program implementation and procedures.

In chapter 3, each of the prevention approaches described includes at least one shaded box that presents information on levels of evidence. These boxes highlight the consensus of the Expert Panel on conclusions that can reasonably be drawn from an analysis of the research and/or practice evidence for each approach. They also indicate the strength of the level of cumulative evidence supporting the conclusions. The criteria for assigning levels of evidence are shown in the following boxes. The first three categories indicate the extent of research and practice evidence for rating the varying degrees of confirmation of positive effect. The fourth category applies to research and practice evidence indicating that a prevention approach is ineffective.

Strong Level of Evidence

Application. Practitioners can use the approach with the most assurance that the approach can produce the effect specified in the evidence statement.

Criteria

a. Consistent positive results of strong or medium effect from a series of studies, including:
  - At least three well-executed studies of experimental or quasi-experimental design OR
  - Two well-executed studies of experimental or quasi-experimental design AND
  - Consistent results from at least three case studies
b. The use of at least two different methodologies
c. Unambiguous time ordering of intervention and results
d. A plausible conceptual model ruling out or controlling for alternative causal paths or explanations

Medium Level of Evidence

Application. Although the number or rigor of the studies reviewed is limited at this time, there is still substantial support for a prevention approach's ability to produce the particular effect specified in the evidence statement. Practitioners should exercise discretion in application and in assessment of process and outcomes.

Criteria

a. Consistent positive results from a series of studies, including:
  - At least two well-executed studies with experimental or quasi-experimental designs OR
  - At least one well-executed study and three prevention case studies showing statistically significant or qualitatively clear effects
b. The use of at least two different methodologies
c. Unambiguous time ordering of intervention and results when so measured
d. A plausible conceptual model, whether or not competing explanations have been ruled out

Suggestive but Insufficient Evidence

Application. The approach has shown promise for the particular effect specified, but it is not well documented. Practitioners should be cautious about using this approach. However, if the approach fits the local situation, practitioners may use it, paying special attention to its systematic testing and documentation.

Criteria

This category is used to describe research and/or practice evidence that (1) is based on a plausible conceptual model or on previous research and (2) is being demonstrated in rigorous evaluation studies or appropriate intervention programs currently in process. One of two conditions typically causes evidence to be described as suggestive but insufficient:

a. In the first condition, the evidence, although limited, appears to support a conclusion, but additional research is needed to fully support the conclusion. This condition often applies to areas in which there has been little study, such as those that are impractical to research or new areas of study.
b. A second condition involves equivocal results. In this condition, a specific conclusion is supported in some studies but is not supported in others.

Substantial Evidence of Ineffectiveness

Application. The approach has not demonstrated the intended results or has shown negative findings for the effects specified. Practitioners are advised not to use the approach at this time.

Criteria

This category describes research and practice evidence demonstrating that a prevention approach is not effective. The criterion for inclusion in this category is the absence of a statistically significant effect or a statistically significant negative effect in a majority of well-executed studies, including at least two quantitative studies with sample sizes sufficient to test for the significance of the effect.

### Using Levels of Evidence in Program Planning

Because prevention activities vary in their emphasis, scope, and content, no two research studies or practice cases are the same. As they differ in the subjects of evaluation and in the methods used, it is difficult to reach a single conclusion about a particular approach. Additionally, there may be varying levels of evidence for different desired results of a prevention approach, as shown by similar findings from more than one study. Therefore, more than one evidence statement may be made to identify and rate conclusions that can be drawn from evidence available on a single approach. For instance, studies may show that a prevention approach has strong evidence for attaining a desired effect in the short term, but suggestive but insufficient evidence for sustaining that effect over time.

The prevention approaches presented in this guide should be considered in light of local circumstances; it may not be feasible to implement only those approaches with a strong level of evidence. Local needs, interests, resources, and abilities - as well as the level of evidence - must all be considered when planners and practitioners make program development choices.

## Recommendations for Practice

Following the evidence-based analysis of each approach, the reader will find a special section outlining recommendations for practice. This section presents the PEPS Expert Panel members' recommendations, suggestions, observations, and interpretations regarding the prevention approach evaluated in the preceding text. General recommendations and suggestions that are applicable to more than one prevention approach appear later in the chapter.

### Types of Recommendations

The recommendations for practice vary considerably in nature and intent. Some are practical suggestions for optimal implementation of a particular intervention, while others suggest techniques and cautions to avoid problems. A few are practical observations about what to expect during certain prevention activities. Others interpret research findings or illustrate the practical context of prevention efforts. Some recommendations reflect expert opinions of the panel members, such as assumptions and hypotheses that drive certain prevention activities. Many represent "best practices" among prevention experts. Some recommendations relate to the implementation of specific prevention interventions. (A comprehensive discussion of implementation is presented in chapter 4.)

## Basis of Recommendations

These recommendations are based on the research and practice evidence reviewed in the Analysis of Evidence section, additional evidence not described in the section, and the professional experience and opinions of Expert Panel members. Many recommendations are derived from the experiences of Expert Panel members involved with research or practice activities that are not explicitly described in the chapter.

These recommendations represent the transfer of practical information from prevention research and practice experts to decisionmakers, such as State and local prevention authorities, other prevention practitioners and researchers, and members of community prevention organizations.

## Content of This Guide

Each of the four chapters of this reference guide explores a different aspect of environmental approaches for preventing problems related to alcohol availability.

Chapter 1, Public Health and Safety Problems Related to Alcohol Availability, outlines the rationale for environmental approaches, presents data on alcohol problems and their effects on public health, discusses the effects of availability on these problems, and defines terminology used in this guideline. The chapter then moves to a discussion of the entities and factors affecting community prevention efforts.

Chapter 2, The Role of the Community in Problems Related to Alcohol Availability, provides a historical overview of alcohol availability in the United States and a look at the modern system of alcohol distribution. It identifies State and local resources that can be used to prevent problems related to alcohol availability.

Chapter 3, Analysis and Recommendations, examines six approaches to the prevention of alcohol availability. Each approach is subjected to PEPS criteria regarding the rigor and extent of existing research and practice evidence. Specific conclusions for each approach are presented in the form of four possible levels of evidence. The level-of-evidence statements are complemented by evidence-based lessons learned and recommendations for practice that draw on both the evidence and the insight of the Expert Panel that reviewed the evidence.

Chapter 4, Planning, Implementing, and Evaluating Prevention Strategies and Policies, reiterates this guideline's focus on policy as an instrument of prevention, as opposed to efforts to influence the behaviors of individuals. The discussion notes that there are significant opportunities for policy-based prevention at the local level and a developing trend in that direction. Guidance for community action is presented in terms of four steps: assessment, planning, implementation, and institutionalizing policies. The discussion concludes with considerations and strategies for documentation and evaluation of alcohol availability policies, programs, and prevention activities. Documentation - the collection and review of information - is distinguished from evaluation, which relies on measurement and comparison to determine the effects of a policy or program. Several types of evaluation designs are reviewed, followed by a discussion of organizational and data collection issues. The chapter ends by indicating the need and potential for advances in research on alcohol availability.

Seven appendices are included to augment readers' understanding of the PEPS process and the content of the guideline, to identify State Alcoholic Beverage Control (ABC) agencies, and to point out areas of information and sources not covered by this guideline.