# Acknowledgments

An extensive review of the evidentiary research and practice literature on a subject such as the one represented by this reference guide is a collaborative venture requiring dedicated participation and skills of many people. We can only attempt to adequately thank these individuals in a forum such as this.

On behalf of CSAP, I would like to express our deep gratitude to members of the Expert Panel for their hard work and dedication in systematizing and synthesizing the evidence on the role of local governments and communities in the prevention of alcohol availability-related problems. Dr. Friedner Wittman contributed his time, energies, and dedication far in excess of what could be expected from him as Chair of the Expert Panel. Of course, throughout this process, the leadership and guidance of the Planning Group has been invaluable. Both the Planning Group and the Expert Panel reviewed several drafts of the guide, and their efforts are reflected in the final version. We would also like to acknowledge the contributions of the Federal Resource Panel in sharpening the focus of the guide and their assistance in accessing fugitive literature.

Many researchers and practitioners in the field reviewed the guideline and provided valuable comments, whose incorporation has substantially improved the final product. Thanks are also due to staff in various CSAP divisions who reviewed successive versions. Special thanks are due to Tom Vischi, Mark Weber, Bob Denniston, Dr. Jan Howard, and Dr. Michael Hilton for their extensive review and comments and to Joan Quinlan, David Wilson, and Barbara Rogers for their help in bringing this reference guide to press. I would be seriously remiss if I did not acknowledge the leadership and support of Dr. Ruth Sanchez-Way, Director, Division of State and Community Prevention Systems.

Last but not least, I want to express my deep appreciation for the staff at Birch & Davis Associates, Inc., who coordinated the development of guideline documents and tirelessly reworked them as they passed through various stages of review. The contribution of EEI Communications, especially that of Alane Keller Ludin and Becki Swinehart, in final copyediting, production, and quality control has been vital and is sincerely appreciated. Executive Editor

## Expert Panel Leading the Development of the Guideline

- Friedner D. Wittman, Ph.D., M.Arch., Chair
- CLEW Associates
- Institute for the Study of Social Change
- University of California at Berkeley
- Berkeley, CA

- Karen Bass
- Community Coalition
- Los Angeles, CA

- Steven A. Darden
- North West New Mexico Fighting Back, Inc.
- Gallup, NM

- Manuel Espinosa
- California Alcoholic Beverage Control
- Sacramento, CA

- Darryl L. Fisher
- City Planning Department
- City of Los Angeles
- Los Angeles, CA

- Norman Giesbrecht, Ph.D.
- Addiction Research Foundation
- Toronto, ON, Canada

- Paul Gruenewald, Ph.D.
- Prevention Research Center
- Pacific Institute for Research and Evaluation
- Berkeley, CA

- Delwin Hanson
- City of Woodland Police Department
- Woodland, CA

- Ralph Hingson, Ph.D.
- Social and Behavioral Sciences Department
- School of Public Health
- Boston University
- Boston, MA

- David P. MacKinnon, Ph.D.
- Department of Psychology
- Arizona State University
- Tempe, AZ

- Linda Major
- Lincoln Council on Alcoholism & Drugs, Inc.
- Lincoln, NE

- Dennis McCarty, Ph.D.
- Substance Abuse Research Group
- Institute for Health Policy
- Brandeis University
- Waltham, MA

- A. James McKnight, Ph.D.
- Public Services Research Institute
- Landover, MD

- James A. Neal
- South Carolina Department of Alcohol and Other Drug Abuse Services
- Columbia, SC

- Francis O'Brien, Jr.
- Pennsylvania Liquor Control Board
- Harrisburg, PA

- Robin Room, Ph.D.
- Addiction Research Foundation
- Toronto, ON, Canada

- Michael Sparks
- North Bay Health Services
- Petaluma, CA

- Alexander Wagenaar, Ph.D.
- Associate Professor, Public Health
- Division of Epidemiology
- University of Minnesota
- Minneapolis, MN

- Elva Yanez
- Consultant
- Albany, CA

### Ex Officio Member

- Prakash L. Grover, Ph.D., M.P.H.
- Division of State and Community Systems Development
- Center for Substance Abuse Prevention
- Rockville, MD

## Advisory Federal Resource Panel for the Guideline

- Tom Albrecht/Terrence Donaghue
- Bureau of Justice Assistance
- U.S. Department of Justice

- Jerry Bowerman
- Distilled Spirits and Tobacco Branch
- Bureau of Alcohol, Tobacco, and Firearms

- Robert Denniston
- Division of Public Education and Dissemination
- Center for Substance Abuse Prevention

- Michael Hilton
- National Institute on Alcohol Abuse and Alcoholism

- Jan Howard
- Prevention Research Branch
- National Institute on Alcohol Abuse and Alcoholism

- Michael Impellizzeri (retired)
- Traffic Safety Programs
- National Highway Traffic Safety Administration

- Hank Oltman
- Corporation for National and Community Service

- Debbie Rudi
- Drug Planning and Outreach
- U.S. Department of Education

- Rick Smith/Laura West
- Alcoholism and Substance Abuse Programs Branch
- Office of Environmental Health and Engineering
- Indian Health Service

### CSAP Staff

- Prakash L. Grover, Ph.D., M.P.H.
- Senior Science Advisor
- Division of State and Community Systems Development

- Gale A. Held
- Director (retired)
- Division of State Prevention Systems

## PEPS PROGRAM Planning Group

- Richard R. Clayton, Ph.D., Chair
- Director, Center for Prevention Research
- University of Kentucky
- Louisville, KY

- Thomas E. Backer, Ph.D.
- Human Interaction Research Institute
- Los Angeles, CA

- Leonard G. Epstein, M.S.W.
- Center for Substance Abuse Prevention
- Rockville, MD

- Bettye Ward Fletcher, Ph.D.
- Jackson State University
- Jackson, MS

- Jean L. Forster, M.D., M.P.H.
- University of Minnesota School of Public Health
- Minneapolis, MN

- William M. Harvey, Ph.D.
- Missouri Institute of Mental Health
- St. Louis, MO

- Ralph W. Hingson, Sc.D.
- Boston University
- Boston, MA

- Jan Howard, Ph.D.
- National Institute on Alcohol Abuse and Alcoholism
- Rockville, MD

- Ford H. Kuramoto, D.S.W.
- National Asian/Pacific American Families Against Substance Abuse, Inc.
- Los Angeles Office
- Monterey Park, CA

- Jeffrey N. Kushner, M.A.
- Office of Alcohol and Drug Abuse Programs
- Oregon Department of Human Resources
- Salem, OR

- Gloria Martin-Payne
- Pennsylvania Office of Drug and Alcohol Programs
- Harrisburg, PA

- Andrea L. Mitchell, M.L.S.
- Alcohol Research Group
- Western Consortium for Public Health
- Berkeley, CA

- Abdin Noboa, Ph.D.
- Innovative Consultants International
- Columbus, OH

- Pamela Petersen, M.P.A., C.A.P.
- Independent Consultant
- Key West, FL

- Eva L. Petoskey, M.A.
- First American Prevention Center
- Suttons Bay, MI

- Robert I. Reynolds, M.A.
- National Center for the Advancement of Prevention
- Rockville, MD

- Robert G. Robinson, Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- Robin G. W. Room, Ph.D.
- The Addiction Research Foundation
- Toronto, ON, Canada

- Zili Sloboda, Sc.D.
- National Institute on Drug Abuse
- Rockville, MD

- Josè Szapocznik, Ph.D.
- University of Miami School of Medicine
- Miami, FL

- Ralph E. Tarter, Ph.D., M.P.A.
- University of Pittsburgh School of Medicine
- Pittsburgh, PA

- Mel Tremper, Ph.D.
- National Center for the Advancement of Prevention
- Rockville, MD

- Friedner D. Wittman, Ph.D., M.Arch.
- CLEW Associates
- Berkeley, CA

### Ex Officio Member

- Prakash L. Grover, Ph.D., M.P.H.
- Center for Substance Abuse Prevention
- Rockville, MD