# Foreword

The Substance Abuse and Mental Health Services Administration's Center for Substance Abuse Prevention (SAMHSA/CSAP) is committed to enhancing prevention activities as planned and implemented by federally funded State agencies and community-based organizations across the country. Through a participatory process involving policymakers, researchers, program managers, and practitioners, the Prevention Enhancement Protocols System (PEPS) is generating products that can substantially improve planning and management of prevention programs, consolidate and focus prevention interventions, and potentially serve as the foundation for prevention studies.

CSAP selected this topic because alcohol use problems affect many individuals and groups in our communities. These include the use of alcohol by underage youth, traffic accidents, violence, and economic and social problems. Approaches that are effective in preventing these problems will improve the quality of life for all community members. Current research and practice indicates that the deliberate management of high-risk alcohol availability situations can reduce these problems. Although communities can manage alcohol availability problems through State and local government entities, many do not fully utilize their powers to do so. Through the PEPS program, CSAP's Division of State and Community Systems Development is providing State and local governments with a set of tools for addressing these problems.

This guideline is designed for broad use. Its intended audiences include not only State substance abuse agencies but also national, State, and local organizations that address issues relating to the availability of alcohol. It is a practical, detailed guide for considering the advantages and disadvantages of specific interventions and for planning prevention initiatives in the community.

The most important aspect of PEPS is the use of systematic protocols to prepare guidelines such as this one. Ultimately, the overarching methodological accomplishments of PEPS may have far greater influence than any single guideline, for they will have given birth to a tradition of development and dissemination of science-based recommendations for the substance abuse prevention field.

Nelba Chavez, Ph.D. Administrator Substance Abuse and Mental Health Services Administration

Karol Kumpfer, Ph.D. Director Center for Substance Abuse Prevention Substance Abuse and Mental Health Services Administration