# Planning, Implementing, and Evaluating Prevention Policies and Strategies

The environmental prevention model presented in this guide differs from American society's traditional approach to alcohol-related problems, which focuses on solutions through work with "problem individuals."

With an environmental prevention model, the focus shifts from individual behaviors to policies and policy changes; from the relationship between the individual and alcohol-related problems to the social, political, and economic contexts of those problems; from short-term program development to long-term policy development; and from individual efforts at problem-solving to collective actions.

Local communities can enter into strong and effective partnerships with State ABC's to prevent problems related to alcohol availability.

This model's significant realignment of focus demands community organization specifically to address problems related to alcohol availability. In fact, the successful development of local policies on alcohol availability depends on collaboration among concerned community members. Such cooperation is not hard to achieve: when individuals are confronted by concrete problems that affect them personally or professionally, they are more likely to work together to help create new policies to protect themselves, their families, and their communities. The task before local organizers is to facilitate the development of informed and capable community organizations committed to taking action to address the problems caused by alcohol availability. The primary functions community organizers must perform are as follows:

- Assemble the community members most directly affected by the problems.
- Collect data that define the scope and specifics of the community's alcohol availability-related problems.
- Consider solutions.
- Develop a plan for action.
- Implement new prevention policies and evaluate their impact.
- Monitor implementation of the action plan and prevention policies to ensure their continuation.

## A Strategy for Managing Alcohol Availability

States and local communities share both the responsibility and the power to solve problems related to alcohol availability. The planning process outlined in this chapter can help communities use their existing powers to become strong and effective partners with their respective State Alcoholic Beverage Control authorities. State ABC agencies generally recognize the importance of local participation in alcohol licensing activities and encourage communities to make full use of their powers and resources in partnership with the ABC.

The environmental planning process outlined here is already in wide use and has been effective in managing alcohol availability. This process applies to all public planning that involves property management for the purpose of protecting community health and safety. Precedents for such a process come from local zoning laws, public health planning authorities, and widely accepted community practices for problem-solving and long-range planning.

### Precedents for Local Prevention Planning

A 1926 U.S. Supreme Court decision found that communities with elected legislatures have considerable powers to protect the "public health, safety, welfare, and morals" of their residents (City of Euclid v. Ambler Realty Co. 1926). For example, cities, counties, and other locally governed jurisdictions have the power to regulate local land use unless State law has preempted these powers. Otherwise, local regulatory powers apply to the use of public property (streets, sidewalks, alleys, and public transportation, to name only a few), to activities at private events; and to programs to encourage prevention policies. Over the past 70 years, many communities have made effective use of local planning and zoning laws to protect public health and safety. More recently, such laws have also been used to help guide community development in ways consistent with State-level economic development policies (Marcus and Groves 1970). It is therefore not surprising that State governments usually recognize the value of local planning and zoning laws and protect their use.

State ABC agencies play an important role in regulating the alcoholic beverage industry and the sale of its products, but they generally leave considerable decision-making power to communities. All States empower local governments to review applications in the State retail alcohol licensing process, to enact local zoning ordinances, and to regulate property owned or managed by local public authorities.

Some States go so far as to give local governments the power to deny alcohol outlet applications to the ABC and to enact local ordinances regulating the sale of alcohol in the community.

### A Practical and Flexible Planning Process

Most communities can successfully adapt the environmental planning process described in this chapter. This planning process works in any city, county, or other geographically defined area with a local legislature that has the power to regulate the use of property. This process can also be used by community agencies both to implement programs that enforce existing laws and to conduct public awareness campaigns.

The environmental concept behind the process means that it is not a formula restricted to particular methods; it works more like a menu of possibilities than as a prescription for specific activities. Within this broad framework of possibilities, each community has the latitude to develop policies and practices that fit with its traditions and available resources.

The strength of this type of planning process is that it lets community agencies and organizations tailor the various strategies described in chapter 2 to their own needs and select one or more of the six prevention approaches detailed in chapter 3. Each of them takes an environmental orientation that focuses on policy changes rather than individuals to prevent or lessen alcohol availability-related problems within the community. As described in chapter 3, those six approaches are as follows:

1. Preventing Availability to Underage Youth.
2. Raising Alcohol Taxes and Prices.
3. Responsible Beverage Service.
4. Changing the Conditions of Availability.
5. Changing Hours and Days of Sale.
6. Community-Based Prevention Activities (which combine elements of some of the other five approaches).

Because the above prevention approaches include policy elements, individuals involved in local policy development should be part of any community effort to affect alcohol availability. This chapter describes processes for working within communities to develop programs and policies to manage problems related to alcohol availability and discusses the assessment, planning, implementation, and evaluation of these processes by the community.

The planning and evaluation processes described later in this chapter do not refer specifically to any of the six approaches. Nevertheless, the planning and evaluation guidelines can assist prevention practitioners and communities in determining which of the approaches to implement and how to foster the collaboration and gather the information necessary to succeed. Case-study examples detailed in chapter 3 illustrate various community-wide initiatives using a single approach or a combination of approaches, such as the Under 21 Enforcement Project, the Midwestern Prevention Project, and the Central Precinct Neighborhood Alliance.

### Strategies for Community Prevention Campaigns

alcohol outlet - a business or location where alcoholic beverages are sold to the public or to a select membership.

Community organizing around alcohol availability-related problems requires bringing people together to discuss their individual concerns and experiences. Meetings of this sort allow participants to get to know one another and to begin identifying problems of mutual concern. Effective organizers recognize that building a strong community action group - one able and willing to work together - is as critical a part of their mission as actually solving problems. Organizers should approach and urge the following individuals and groups to take part in any community prevention effort:

- Advocacy groups.
- Alcohol prevention agencies.
- Business leaders in the community, including alcohol retailers.
- Clergy and church, synagogue, and temple associations.
- Community leaders and activists.
- Local or national chapters of Mothers Against Drunk Driving (MADD).
- Neighbors and neighborhood associations, including crime-watch groups.
- School principals and other school officials.
- Self-help recovery groups.
- Social service and other community service agencies.
- Substance abuse treatment programs.

In communities that have broad-based and widely shared concerns about alcohol availability, the most appropriate community action strategy is to bring participants together to identify specific and general problems, review the findings, and come to consensus on a plan for action. City and county officials, residents, business leaders, neighborhood and civic groups, and others can then develop a planning process marked by shared decision-making and technical cooperation across a broad segment of the community.

Planning groups that grow out of this process will include representatives from the staffs of city or county government offices (e.g., the planning department or city manager's office); the local planning commission or city council; the police department or sheriff's office; on- and off-sale alcohol retail outlets; the Chamber of Commerce; community-based grassroots organizations; civic groups; the religious community; and schools.

No community action group will coalesce overnight; organizers and participants must be patient and strive to help the new group develop the skills to work as a unit capable of developing its own approaches to identifying and then solving problems. This takes a lot of time and substantial resources, but the effort is worth it if the result is an organization ready and able to take on the community's troubles. The organizer's goal thus should be twofold: first, to help the group itself develop, and second, to help the group maintain its focus on constructing a workable plan to effectively reduce alcohol availability-related problems in the community.

This guide as a whole, particularly through the four-step planning process described below, presents communities with an extensive array of potential prevention ideas, tasks, actors, and activities to think about implementing. Neither the overall guide nor the recommended four-step process is intended to dictate any narrow path that must be followed, but rather to offer a wide range of options for local groups to consider. Whatever prevention approach or approaches a community decides on, its action plan should be mutually agreed upon and include overall goals as well as specific measurable objectives.

As a community group matures, it needs to develop a structure, define its goals and objectives, and select one or several prevention approaches to implement. The coalition also has to identify who holds ultimate responsibility as "the planning group," and then must finalize a plan for action and a time frame for executing it. Once those components are in place, the group can draw on the experiences of prevention practitioners to develop an efficient process for approaching agency staff and designing community education and training programs. At the same time, it is important to set up a monitoring system, adopt enforcement policies, craft an evaluation plan, assign responsibilities for implementing the plan, and, finally, to establish a policy review board.

### A Four-Step Planning Process

Any coalition that emerges as a community's planning group for establishing and maintaining policies on alcohol availability will likely take one of several forms. Experience to date suggests that such planning groups often grow out of continuing ad hoc coalitions of community organizations, from policy working groups within city governments, or from local nonprofit agencies that have assumed leadership over the local planning process. This chapter describes four basic steps that any of these diverse community groups can follow to become continuing planning groups centered on maintaining public health and safety through policies regarding alcohol availability at the local level.

Depending on the nature of the community and the problems its activists seek to address, any combination of a variety of activities can be undertaken to attain local goals within the overall structure delineated by the following four steps:

1. Laying the Groundwork: Assessment. The first step in grassroots prevention involves determining and demonstrating the link between alcohol availability and alcohol-related problems in the community. This step is critical for two reasons: (1) to determine the necessary regulatory policies, prevention approaches, and programs that need to be developed, and (2) to ensure that all new policies and procedures rest on a firm empirical and legal footing.
2. Organizing the Community: Planning. The second step is local organizing to develop a core of dedicated workers, to win broad public support, and to gain cooperation from and coordination with local agencies, policymakers, and others who influence or determine what new activities and policies are developed in the jurisdiction. With the help of professionals experienced in community-based prevention efforts, the initial planning group will then break into subgroups to perform specific functions, such as the following: (1) task forces and technical work groups to undertake specific prevention initiatives; (2) an information and community education component that will use the problem-assessment data collected in Step 1 to make the case to the public of the need for prevention initiatives aimed at reducing identified problems; (3) a general planning committee to encourage broad community participation and raise local awareness about availability-related issues; and (4) a steering committee to oversee the entire effort and to serve as liaison with key public agencies and other community organizations.
3. Taking Action: Implementation. The third step is to put into effect the policies and programs generated in Step 2. Implementation activities will vary depending on whether the community decides to enact new policies, to review existing policies, to initiate prevention programs, or to combine two or all three of these activities. Once a new program or policy is adopted, it must be applied and enforced consistently throughout the community.
4. Institutionalizing Policies: Continuation. The fourth step involves making new policies and programs part of community life, which requires consistent effort and vigilant monitoring. Implementation over time presents several challenges, including the possibility that new issues may emerge that require policies to be reviewed and perhaps revised. On the other hand, as problems lessen, the need for monitoring them may decrease. Care must be taken, however, not to let hard-earned gains slip away through a lack of community vigilance as time passes or through a failure to stand up to growing pressures to relax or modify worthwhile policies.

In practice, the activities listed in these four steps will not necessarily be sequential and may often overlap. Planning groups will find that they must revisit previous steps as situations change and additional information and resources become available.

In any case, hiring one or more well-trained and well-supported community workers is crucial to stimulate the growth of an ad hoc community coalition into a mature planning group. The examples of community organizing efforts in chapter 3 and in Appendix E show how a few experienced workers can move even a large community to adopt local policies that effectively control alcohol-related problems.

## Step 1 - Laying the Groundwork: Assessment

Successful local prevention initiatives begin with collecting appropriate data and presenting an analysis of the findings that demonstrates the link between alcohol availability and community problems. Fact-filled presentations can create an energy that moves individuals and groups into action. Such presentations also create a foundation on which community members can work together to prevent or reduce availability-related problems. Showing local residents the connections between alcohol availability and problems they have experienced in their communities helps them see the scope of the problem and the need for action.

An important issue is often overlooked in the early planning stage. That is that the data gained through local problem assessment might prove essential for the legal defense of prevention policies and conditions that affect the use of private property.

Finally, and most important, the data collected for planning are essential to create a baseline and a framework for evaluating the community's efforts. Accurate assessments of both the progress of community efforts (process evaluation) and of each initiative's success or failure (outcome evaluation) depend on the thoroughness and accuracy of the baseline.

### Identifying the Problems

When using an environmental planning process, practitioners look not just at the "problem behaviors" of individuals but also at the local environment and at the systems the community has set up to manage alcohol availability. Initial data collection should thus include the following considerations:

1. Current community attitudes and practices regarding problems that seem to result from alcohol availability.
2. Current public response to high-risk alcohol outlets.
3. Current regulatory policies and procedures that need to be reviewed or revised, such as those regarding public nuisances, safety, land use, and public gatherings.
4. Extent and nature of the problems related to alcohol availability.
5. History of any previous efforts in the community to regulate alcohol availability, including both those that have succeeded and those that have failed.
6. How and where alcohol is sold in the community.
7. Physical location and boundaries of the problems in the community.
8. Planning and zoning ordinances that have an impact on alcohol availability.
9. Situations in which the problems occur, such as at community fairs, certain drinking establishments, fraternity parties, high school proms, and stadiums.
10. The extent to which the six prevention approaches presented in chapter 3 are currently practiced.

Sometimes priority problems are easy to identify because the community is well aware of them and motivated to correct them. Often, however, concerned individuals will have to collect and review the data listed above, talk with those who live, work, and conduct business in the community, do surveys, and review additional data before they can begin to develop a consensus on problem identification and to set goals for the changes they wish to effect.

### Identifying the Stakeholders

Stakeholders are individuals or groups with an interest in alcohol availability issues such as drunk driving, alcohol-related violence, alcohol-related problems in the workplace, loitering, and neighborhood blight. Examples include organizations and individuals who hold the decision making power in the community, operators and staff of alcohol outlets, and those who are negatively affected by the problems. Identifying the stakeholders helps community workers discover who will work with them and who will work against them.

To identify stakeholders, ask the following four questions:

1. Who holds the power to effect change?
2. Who has access to that power?
3. Who is negatively affected by an alcohol availability problem?
4. Who has something to gain by ignoring the problem?

Ideally, all the stakeholders will join in efforts to find solutions to identified problems, but the answers to the four questions above will probably reveal a variety of interests. For example, some organizations and individuals, including elected officials and local government representatives, with the power and influence to bring about change may oppose such change or have conflicting interests that make them reluctant supporters. Therefore, careful attention must be paid to the vested interests of the various stakeholders when developing proposals and garnering support for action. Failure to correctly assess the situation and to craft a strategy accordingly can be a recipe for defeat. The section below on Step 2 - Organizing the Community: Planning elaborates on this point.

One effective way to identify stakeholders is to use the four questions listed above as the basis for a stakeholder questionnaire or survey. The best way to develop such a questionnaire is to select specific settings and circumstances in subcommunities where alcohol availability is a problem. The survey can then explore the perspectives and roles of people who live or work in the area; business owners and managers (both alcohol-related and otherwise); and government officials, agencies, service groups, and other interested parties.

### Collecting Data on the Problems

To demonstrate the link between community problems and alcohol availability, it is essential to collect data that help describe and define problems related to alcohol availability. Important data to list are the problems, the context (at a public event, outside a tavern, etc.), and the geographical location for each subset of data collected. Such descriptive information will both document the link between alcohol-related problems and alcohol availability in the community and create an official record that may be used to justify public action. (See the section on Identifying Sources of Data for Analysis later in this chapter.)

#### Data Sources Within the Community

Local public agencies have a good deal of information that can help in documenting alcohol availability-related problems. Data from the police department, the planning department, the parks and recreation department, and the State ABC can help establish the extent of alcohol-related problems and the situations in which problems occur. (See the section on Tasks of Local Officials and Other Interested Parties under Step 3 - Taking Action: Implementation for a clarification of the roles public agencies might play.)

Additional community sources of data include the following:

- Archival reports and documents, including official data from public agencies, reports from local agencies, and newspaper coverage of alcohol sales, drinking-related problems, and numbers and types of outlets.
- Direct observation of events or activities in or near licensed premises and interviews with patrons, servers, and members of the general public.
- Discussions with local agencies and organizations working on this topic.
- Discussions with technical experts or individuals who have special knowledge of the relationship between alcohol availability and community problems both within and outside the community.
- Literature reviews of alcohol availability and its associated public health and safety aspects.
- Special statistics collected by law enforcement officers and other special tabulations of local data highlighting problems possibly springing from alcohol availability.

#### Review Experiences of Other Communities

Many cities and counties across the country have been active in developing ways to address alcohol-related problems in retail settings. Communicating with agencies, organizations, and individuals from other communities about their local management experiences can save valuable time, boost morale, and help focus energy within the community at hand.

#### Consider Seeking Technical Assistance

Many individuals and agencies that specialize in a particular subject area may be willing to help community groups collect data for assessing their needs. This expertise may be available at little or no cost from public agencies such as State ABC's, State substance abuse agencies, and local police and planning departments as well as from universities, foundations, or publicly funded programs such as legal aid and health planning foundations.

## Step 2 - Organizing the Community: Planning

Organizing a community around an issue requires a great deal of effort, but this effort can have dramatic payoffs. When a community takes on a collaborative effort, its power to effect change can be remarkable.

### Community Action Is Effective

The work of Saul Alinsky (1981) established the importance of organizing people to gain power in order to change living conditions in the Chicago Area Project in the 1930's. The civil rights movement is another excellent example of the power of large numbers of people working at the grassroots level to change the direction of the country. Similarly, the student movement against the role of the United States in the Vietnam War spawned many subsequent community-based organizing activities and still serves as an example of effective organizing.

The alcohol prevention field also has significant experience in using community organizing to address problems associated with alcohol availability. In fact, the history of community-based organizing efforts dates back to the early 1800's, when local community groups organized temperance movements in response to the rapidly rising availability of alcohol. One of the many lessons learned from that period is that well-organized groups of people can make significant changes in how, when, and where alcohol is sold and served. Several studies and handbooks on grassroots organizing for community change provide useful information about community organizing to address alcohol availability issues (Bobo, Kendall and Max 1991; Lofquist 1989; Zander 1990.)

Modern-day organizing efforts to address community problems with alcohol availability date back to the mid-1970's, when organizing activities took place in both low-income and middle-class communities. The low-income community groups in inner cities, for example, began demonstrating against continuing problems with alcohol outlets in declining commercial areas. They were concerned about the negative impact of alcohol availability on their community members' health and the availability of social services. Parents and educators in middle-income groups, meanwhile, took action against the easy availability of alcohol to junior high and high school youth. They were reacting to the impact of alcohol advertising appealing to youth through billboards and promotional displays, and to the ease with which young people could obtain alcohol at off-sale outlets.

### Identifying the Scope of the Community Action Plan

Often, a major concern of community activities is determining who or what groups hold the final power and authority to make decisions about change and how to influence those groups. Multiple community constituencies generally determine what to do and how to go about it. To keep organizing efforts focused on the problems of alcohol availability, goals and objectives should be clearly formulated and, as soon as reasonable, one or more of the six prevention approaches presented in chapter 3 selected for implementing policies regulating alcohol availability.

Strategies for organizing and selecting prevention interventions are greatly influenced by the scope of the effort. Case-level organizing addresses problems that arise from existing settings of alcohol availability in particular establishments at specific locations. Community-wide organizing emphasizes a long-term process to develop public policies and programs that reduce or prevent alcohol problems in various types of settings (e.g., bars or restaurants) and various areas of the community.

Community organizers working on availability issues need to understand clearly the differences between mobilizing for immediate action and organizing for long-term community improvement. An immediate action initiative, for example, may demand a different composition of community members than an effort to make long-term changes. The scope - immediate action or long-term change - also shapes what activities will be undertaken and the way many other issues will be handled. Power, control, community access, and goals are all colored by the decision to organize for immediate action or for long-term change.

In addition, community organizers must consider how their efforts to organize will promote or hinder decisive, immediate action to prevent or reduce specific alcohol availability-related problems. Community organizing efforts, are, in and of themselves, interventions that will change the community. Finally, organizers must be aware of the impact their efforts will have on a community's self-image and sense of power to effect changes that will perhaps go far beyond the initial efforts.

### Additional Strategies for Community Campaigns

#### Work With Agencies and Organizations

As the community begins its work, it may discover that some local agencies and organizations have already been involved in efforts to limit alcohol availability. It is often natural for these groups to take a leading role in the new initiative, as they may have already developed contacts and influence with the police, planning departments, and other community organizations.

#### Build Broad-Based Coalitions

It is important to establish a broad-based constituency of support to address alcohol availability problems. Building coalitions is an expanded form of community organizing; such coalitions are made up of a number of community-based and grassroots organizations that share common goals or concerns. The more a coalition represents the numerous facets of the community and shares a common goal, the more powerful and respected it will prove to be.

#### Integrate Technical Assistance From State, County, and Educational Institutions Into the Planning and Proposed Activities of Local Groups

State ABC's, Single State Agencies (SSAs), universities, and local police and planning departments may all have expertise and assistance that is readily available at little or no cost.

#### Mobilize Neighborhoods to Work With High-Risk Outlets

High-risk alcohol outlets endanger the public health, safety, and well-being of a community. Still, opinions about what endangers the welfare of the community may differ depending on one's perspective. In general, outlets can be classified as high-risk if they engage in one or more of the following activities:

- Advertising promotions that encourage overconsumption, such as multiple drinks for a single price.
- Aggressive sales practices (sales with the intent to intoxicate) that endanger outlet staff, patrons, and others.
- Contributing to, or neglecting to address, drug trafficking on the premises.
- Encouraging or allowing loitering near or on the premises.
- Ignoring problem patron behavior.
- Marketing beverages such as fortified wines to alcoholics.
- Neglecting to address on-site consumption of alcoholic beverages from open containers in an off-sale outlet or on the surrounding premises.
- Not allowing for proper lighting or failing to institute other crime-prevention methods in known high-crime areas.
- Resisting cooperation with the police and neighborhood groups that present complaints.
- Selling to obviously intoxicated persons.
- Selling to underage youths.
- Violating restrictions on hours or days of sale or other license requirements.

Sometimes problem outlets do not respond to conventional law enforcement techniques; in some cases local planning officials are not able to regulate them through existing zoning ordinances, and State ABC regulations appear to be ineffective. In these circumstances, community organizers have been successful in working with neighborhood residents, churches, and businesses as well as local social and health service programs to take the lead in enforcement activities and in creating stronger ordinances and public policies.

Mobilizing a neighborhood to work together with high-risk outlets, police departments, parks and recreation departments, city attorney's offices, and community development departments has proven much more effective than simply focusing on individual problem outlets. Broader prevention strategies can set policies, formulate ordinances, and make an impact on the environments where alcohol is made available - especially high-risk outlets.

#### Use Tragedies as a Mobilizing Force

Tragedy often prompts a community to take action. Tragedy-based organizing usually occurs in communities frustrated at the persistence of availability-related problems and a seemingly inadequate official response to them. An excellent example is MADD, a group founded by Candy Lightener after her daughter was killed by a thrice-convicted drinking driver. Similar local actions have sprung out of other personal tragedies. Practitioners should be sensitive to this opportunity and use a community's readiness to act after a tragedy.

#### Conduct Social Marketing and Media Advocacy

The news media offer a very powerful tool for defining and marketing the need for change. Social marketing is more general and frames public education and awareness of prevention issues in terms that appeal specifically to the pro-prevention values of the audience. Media advocacy has more specific goals and combines community organizing, public policy advocacy, and the use of several media sources to promote specific prevention policies and to influence those who have the power to make policy changes. A small group of individuals using media advocacy skills can have a significant impact on citizens' views (Wallack et al. 1993).

#### Consider Benchmarks to Measure the Effectiveness of Organizing

The following four questions help organizers check their progress:

1. Is the community selecting reduction of alcohol availability problems as a concrete objective that everyone will work to support?
2. Has the community defined a productive community-level planning process that achieves results?
3. Is the group integrating professional expertise and the operation of public agencies into its work?
4. Does the group adequately explain the local community's problems to the larger community, and does it take part in the larger community's political process?

## Step 3 - Taking Action: Implementation

Implementation of specific policies and practices to reduce high-risk environments of alcohol availability is the next step after identifying the nexus between alcohol outlets and alcohol problems and organizing community agencies and groups to take action against the problems. The implementation of activities designed to result in substantial reductions in community health and safety problems associated with high-risk environments often requires significant changes in local practices and patterns of alcohol availability.

These changes may involve modifications to current practices, such as better enforcement of existing ABC regulations and local laws related to alcohol, or the institution of RBS training requirements for managers and staff of alcohol outlets. The changes may involve strengthened review procedures and standards affecting the sale and service of alcohol, such as higher standards for alcohol-safe and alcohol-free events at local fairgrounds, or the changes may affect patterns in the distribution and operation of new alcohol outlets, such as a moratorium on new alcohol outlets or alcohol outlet transfers in high-crime areas that already have a high concentration. These changes may apply selectively to a few outlets on a case-by-case basis or may apply generally to all outlets of a particular type, for example to all bars or to all off-sale outlets. The changes also might apply prospectively only to future establishments, or might apply to both existing and future establishments.

Whatever their scope may be, all such changes to availability-related practices and policies involve three groups of stakeholders: (1) owners and managers; (2) occupants and neighbors; and (3) officials and other interested parties. Each of these three stakeholder groups exerts a particular kind of influence on activities associated with the alcohol outlets in question, and each kind of influence is important to implementation of the community's activities to manage problems associated with alcohol outlets. The three groups break down as follows:

1. Owners and managers operate the alcohol outlets. They determine who may enter and who may stay. They design the environment and manage the staff who operate it. They also set the rules for patron and guest behavior while in the establishment or attending the event where alcohol is present. These rules include provisions for the exit of staff, patrons, or guests if their behavior is not acceptable. Owners and managers also are legally and financially responsible for the environment.
2. Occupants and neighbors use the environment. Their uses of the setting and their behaviors at the event establish the kinds of activities and the qualities of experiences associated with the alcohol environment. Although adult occupants and neighbors are fully responsible for their individual behavior in connection with these activities, they are also influenced strongly by the behaviors of other occupants and neighbors and by the rules and expectations of the facility's management.
3. Officials and other interested parties have particular obligations or interests in controlling the environment. For example, State ABC and local police officials are responsible for enforcement to protect public safety. Public health officers and social service providers are responsible for guarding against threats to the public health and well-being posed by the environment. Banks and insurance companies are concerned that an establishment's financial operations are sound and legitimate.

Successful implementation of prevention and problem-reduction initiatives at the community level depends upon the willingness and capacity of these stakeholder groups to work together effectively to accept changes that will reduce public health and safety problems (Wittman and Wright 1997). The immediate focus in implementing such changes is on the management policies and practices for the sale and use of alcohol at the establishments or sites in question. The burden of change falls primarily on the owners and managers, because the rights and responsibilities of ownership require these parties to be the ones who initiate the actual changes in an establishment's policies and practices.

But outlet owners and managers cannot be expected to act alone; the activities of occupants and neighbors also are major factors in reducing problems. These occupants and neighbors must accept and comply with any changes if the changes are to be successful. Similarly, commercial establishments and public-use facilities do not exist in a vacuum within their surrounding communities. Operators and site managers often can use help from local agencies and from their peers to understand the prevention policies and practices that are being put in place.

Because the actions of these three stakeholder groups are so closely intertwined in the local community, successful adoption of changes in the practices and policies regarding alcohol availability requires deliberate and continuing efforts by all of the stakeholder groups to work well with each other.

### Establishing Task Forces to Implement Prevention Initiatives

It is important to understand the relationship among the three stakeholder groups and the community organizing activities described in Step 2. Each of the three stakeholder groups is likely to do some self-organizing among its own members, particularly if it perceives the other two groups doing likewise. The three stakeholder groups will have areas of agreement and disagreement based on each group's interests; subgroups within each stakeholder group also may have some differences. Since the three groups' interests are not identical, in some cases they will conflict, and in some cases they will be complementary.

The groups' interests may be highly complementary regarding general goals for the protection of the community's public health, safety, and well-being, but may differ considerably on the best policies and practices for reaching these goals. Community prevention workers can be influential in helping these stakeholder groups work cooperatively with each other, emphasizing resolution of differences rather than their perpetuation, to achieve changes in practices and policies that reduce the community's availability-related public health and safety problems. Often, apparent differences can be resolved in a cooperative manner. Even if the differences do not disappear, the implementation process such as the one described here can still be used to achieve changes that significantly reduce or prevent availability-related problems.

It is important to undertake the process of implementing prevention initiatives for specific alcohol-related problem environments through the organized efforts of a community action group as described in Step 2. Community prevention workers can provide coordinating and communication assistance to form a task force or working group dedicated to realizing the prevention initiative that has been selected and specified through Steps 1 and 2. These workers can also help with any special technical assistance that may be needed. For example, a task force dedicated to establishing an effective RBS training program may need a technical committee to identify the best training curriculum.

A community action group's other components are vital to help facilitate the task force work in which the three stakeholders are engaged. These other components of community planning efforts include a steering committee to help with liaisons to key agencies and organizations and with monitoring and evaluating prevention efforts; a public information committee to create press coverage and other community education activities; and a planning committee to build a broad base of community support and understanding for the initiative.

Even if the specific prevention initiatives are modest ones aimed at a specific alcohol outlet or a particular practice, the importance of a community-level effort that involves these several sources of support should be emphasized. Only rarely are small neighborhood groups or concerned individuals able to prevail against a troublesome site for alcohol problems. Even then the success usually will come at great personal cost and will probably be reactive, responding to a situation in which considerable harm and loss have already occurred, sometimes over a period of years. Furthermore, a single success of this type is unlikely to have major policy implications that will prevent a recurrence of the problem. Organizing in advance, as shown by the examples in chapter 3, provides far better chances for success.

The following discussion reviews the tasks that each set of stakeholders can set for themselves to help implement prevention strategies for managing alcohol availability in a community.

#### Tasks of Owners and Managers

Many owners and managers of alcohol outlets as well as sponsors of events at which alcohol is present support their communities' local availability policies and comply fully with them. The thrust of prevention implementation activities should therefore facilitate the positive participation of these owners, managers, and sponsors, and take a firm stand with those who do not comply with local policies.

The following are some of the tasks that owners and managers should take on to maintain a healthy and safe environment for both their business and the community at large:

- Engage in a process of self-monitoring. Nearly all alcohol retailers stay compliant with local and State ordinances and are concerned about maintaining good relationships with their patrons and neighbors. Most retailers will be willing to meet the conditions imposed on their outlets, and they should be encouraged and rewarded for doing so by their own trade and business associations, by public agencies, and by community groups and organizations.
- Help develop policies and procedures. Merchants should meet periodically with city agencies and involved community groups to jointly construct a framework for taking the steps required to comply with local policies and to establish a common compliance timeline for merchants. It is also important to assess what support merchants need from the agencies and the community. This open exchange brings merchants into the decision making process and facilitates a smoother implementation of new policies and changes.

In turn, municipalities should do the following:

- Develop a peer program in which owners and merchants help one another adopt training programs on the trouble-free use of alcohol. Many outlet owners and managers have had no specialized training in preventing problems related to the availability of alcoholic beverages. Some owners and managers may have difficulty relating to customers and neighbors, especially if their cultural backgrounds differ. A prevention plan developed in collaboration with owners and managers should address special training to prepare merchants for trouble-free sales.
- Support unannounced visits to monitor compliance. Some municipalities conduct "sting" operations designed to ensure that merchants are in compliance with laws governing the sale of alcoholic beverages to underage youth and other restrictions specific to the community. Sting operations put merchants on notice that the community is willing to enforce its laws.
- Reward merchants who consistently comply with the laws and avoid merchants who do not. Information about an alcohol outlet's willingness and efforts to operate within the law should be acknowledged and published, and other merchants should be called upon to follow suit. Positive promotion of compliance can help establish community standards for sales and service practices in which prevention is accepted as a desirable norm. Local business associations for alcohol retailers should make a point of formally endorsing the community's policies for preventing problems with alcohol availability, and should exclude or put on probation members who do not endorse the policies or are not in compliance with them. Landlords should be encouraged to include community standards for alcohol policies in their lease agreements with tenant alcohol retailers, and to withhold lease renewals pending compliance with those policies.
- Seek economic alternatives to excessive dependency on alcohol sales. Retailers should work closely with their local community to lessen their dependence on alcohol sales. In this area, which has received little study to date, local action will depend heavily on the community's creativity as well as its economic conditions. For example, steps may be taken to encourage increased neighborhood patronage of outlets that shift their merchandise lines away from retail sales of high-risk alcoholic beverages. The local community's economic development offices can offer incentives that help retailers make these shifts.

#### Tasks of Occupants and Neighbors

Implementing new local alcohol availability policies requires the continued participation of community groups and organizations. The policy making process requires local zoning officials or legislative bodies to balance the claims of alcohol retailers and hosts against the concerns of local groups and individuals. Officials responsible for alcohol sales in public facilities and at public events also have to consider the desires of these two constituencies. Concerned community groups and individuals, with the assistance of public health and safety officials, need to speak out as well to clearly show the harm to public health and safety that is likely to result if availability problems are not addressed.

If a prevention program is to succeed, local groups and organizations must take the time and effort to document the community's alcohol availability-related problems; coordinate protests with public health and safety agencies; attend hearings that review applications for retail outlets; and determine whether policies are being adequately enforced.

Along with concerned individuals in the community, local organizations and groups can provide critical support for prevention initiatives. For example, groups can offer the use of their facilities for meetings; recruit volunteers from among their members; provide space in their newsletters for promoting community organization activities; and invite representatives from the prevention program to speak at their meetings.

Effective prevention programs that bring about lasting change are labor-intensive and require continued participation; it is not the work of a day, a week, or a month. In addition to regular and ongoing participation in outlet-related prevention matters on a case-by-case basis, communities that want change must take on the following critical tasks:

- Support local community policing programs and public agencies. It is also important to make the public aware of the community's backing for them.
- Participate in local nuisance abatement and code enforcement activities. This can be accomplished by helping to document the pattern of problems that must be shown before official action can be taken against a problem outlet. Establishing such a pattern requires credible documentation gathered over a period of time with a recording system that captures repeated problems as they occur.
- Continue to learn about alcohol availability. The form and nature of problems related to alcohol availability vary from community to community. Individuals as well as local groups and organizations can conduct assessments of high-risk availability and of the role alcohol availability plays in the community. Sharing this information among local agencies and organizations helps each group to broaden its understanding of the issues.
- Tap into the experiences and support systems of other groups. Local substance abuse and treatment and recovery programs have a wealth of experience and are important supporters of continuing and expanding policies to prevent alcohol-related problems.
- Add an alcohol policy element to the community's general plan. It is also important to promote a periodic public review of the progress of public agencies toward meeting the plan's goals.
- Solicit the support of local businesses. The local business community, as represented by local business associations such as the Chamber of Commerce, can actively encourage alcohol merchants, restaurateurs, and bar owners to operate well-run establishments - what writer Ernest Hemingway called "a clean, well-lighted place." In the course of the problem assessment process, community organizations can demonstrate to the business community how much there is to be gained by showing concern for local public health issues and the role alcohol availability plays in creating public health and safety problems.

#### Tasks of Local Officials and Other Interested Parties

Local public agencies have major responsibilities for implementing local alcohol availability policies, the effective administration of which requires such cooperation among city and county agencies and the State ABC. In the 50 years following the repeal of Prohibition, local governments generally viewed their responsibilities regarding alcohol availability as a matter for law enforcement, and often relied heavily on their State ABC's to share these law enforcement duties as well as to take care of all the other issues related to retail alcohol outlets. Today, in light of research findings and practical experiences such as those described in chapter 3, many city and county governments have begun to realize that local governments should perform several other functions as well to reduce availability-related problems (Wittman 1986, 1997). Among these tasks are the following:

- Assume leadership in establishing policies for preventing availability-related problems. Local governments' support for public prevention policies and related community activities is essential to prevent and reduce alcohol availability-related problems. Recognition of this responsibility by elected and other highly placed local officials such as mayors, city managers, and county administrators sends an important message to all stakeholder groups and to the general public - that is, that the community takes seriously the public health and safety problems associated with alcohol availability and will make full use of its resources to minimize these problems as part of its general responsibility to its residents, workers, and visitors. Occasional public announcements of this commitment at appropriate times and places will signal the locality's continuing commitment to these activities.

- Share oversight duties regarding alcohol availability among local departments and agencies. It is crucial that oversight duties be spread among the following seven local entities:
  1. Police department. In addition to continuing their focus on enforcement of State ABC regulations and local ordinances related to alcohol outlets, local police departments can initiate preventive policing, which emphasizes ensuring compliance and mitigating problems before they develop rather than punishing violators after the fact. Examples of such preventive policing include careful reviews of alcohol outlet applications for state licenses and local zoning permits; decoy-buying operations to discourage alcohol sales to underage youth; preventive visits to outlet operators and neighborhood groups to invite contact with the police at the first signs of problems; nuisance abatement efforts; consultations with outlet operators on crime prevention through environmental design; and consultations with other city departments on crime prevention and compliance issues related to alcohol availability.
  2. Planning and zoning department. Local planning and zoning departments are often underutilized as resources, even though they can do a great deal to reduce and prevent problems related to alcohol outlets (Wittman 1994). For example, a local municipality can employ conditional-use permits and other land-use regulations to facilitate case-by-case oversight of each outlet, to reduce high outlet densities, and to establish preventive conditions for outlet operations as described in chapter 3. In addition, planning and zoning departments can maintain separate files on retail alcohol outlets to facilitate case reviews and to study problems with aggregates of outlets by outlet type or selected geographic areas. They can also conduct periodic code enforcement reviews and nuisance abatement activities at alcohol outlets and work closely with the State ABC and the local police department on outlet reviews and studies. Establishing an "alcohol outlet desk" in planning and zoning departments as the responsibility of a senior planner can help focus and coordinate these activities, maintain continuity, and provide rapid responses to queries from community groups and alcohol retailers.
  3. Parks and recreation department. Because these departments are usually responsible for the management and coordination of all activities at public events and in public places, they should establish clear standards for the use of alcohol at short-term activities at these venues. Examples of such standards include the posting of public notices and the publication of policies regarding alcohol-free and alcohol-safe uses of public facilities. For public areas where alcohol use is permitted, parks and recreation departments should provide guidelines that identify the responsible beverage service standards to be followed. Some State ABC's provide such guidelines for alcohol-safe events and encourage local jurisdictions to adopt them.
  4. Housing and community services department. A high proportion of communities' alcohol-related problems occur in residential settings in the form of domestic violence and nuisance disturbances (Wittman and Harding 1998). Some local housing departments are exploring ways to work with landlords to develop apartment and rental-house policies that prevent or reduce these problems, and are assisting domestic violence teams of police and social service department representatives to work with the owners and managers of these facilities and to make contact with residents.
  5. Community economic development department. Municipalities can look more closely at the actual costs and benefits associated with alcohol outlets as participants in community development projects. Some California cities, including Los Angeles, Oakland, and Santa Cruz, have established fee levels for city services that reflect alcohol outlets' greater demands and thus costs for police services (calls for service) and land-use administration (zoning hearings and outlet monitoring). Cities also have begun to look at the appropriate role of alcohol outlets in redevelopment and special area development plans. For example, "alcohol outlet elements" have been included in redevelopment plans in Hayward, California, and in other community rebuilding plans (see appendix F) to make sure that outlets do not contribute disproportionately to police workloads and thus displace other demands for their services.
  6. City attorney's office. City attorney's offices provide support for local licensing and enforcement activities that involve court cases. These offices also check the relationship between local ordinances and State ABC regulations to make sure that State law does not preempt local ordinances (State law usually does not preempt local zoning or other ordinances regarding the use of alcohol on city-owned properties). A city attorney's office can also monitor continuing legal issues associated with local management of alcohol availability and conduct research to identify effective alcohol ordinances in other localities.
  7. City manager's office. Expanding multiagency responsibilities for local management of alcohol availability requires coordination at the city manager or mayoral level. Coordinated activities can be directed toward alcohol outlets case by case or in the aggregate for policy planning, research, and trend analyses. For example, some cities create special task forces and code enforcement teams to foster interagency cooperation behind actions against "hot spots," areas that are the site of high levels of police and social problems. Some cities also maintain alcohol-policy working groups to coordinate actions to regulate alcohol outlets before problems develop.

- Collect and manage community-level data on alcohol outlet performance. Cities and counties are well positioned to collect data on alcohol outlet operations within the contexts of time, location, and type of setting. Police and planning departments can readily establish information systems for collecting data on a continuous basis for outlet-related police problems and land-use issues. These data, displayed in geographic information system maps, can be used in both case-by-case and aggregate planning and analysis for areas of any size or shape, including police beats, census tracts, and planning districts. Alcohol outlets can be described by land-use type (convenience store, cabaret, bar, etc.) or by their State ABC license-type designation (Wittman, Harding, and Sparks 1997). Currently, few cities or counties make much use of local police and land-use data to examine alcohol outlet-related problems. This situation is ripe for change, as recent technological breakthroughs have made available computer information systems that combine police-problem data, land-use data, and geographic area descriptors in a single, easy-to-use system. These data systems are rapidly becoming even easier to use as well as less expensive as the necessary software continues to be refined and as hardware prices keep dropping (Harding and Wittman 1995). Complete systems are currently available for about $10,000 to $15,000.
  1. Create a cross-agency local planning information system. A local planning system that is sensitive to alcohol-related problems can assemble information from several public agencies, particularly police and planning departments, about aggregates of alcohol-related problems by time, type of setting, and location (Wittman and Harding 1993).
  2. Provide information about alcohol outlet distribution and substance abuse problems. Information regarding outlet distribution and related substance abuse problems is essential for documenting alcohol-related problems and monitoring them over time. Police calls-for-service logs and incident reports can be streamlined to provide this information.
  3. Use local data to support community planning. Policies regulating local alcohol availability should grow out of a thorough study of local data showing the relationships between alcohol availability and alcohol-related problems (Florence Dolan v. City of Tigard 1994).
  4. Ensure routine and timely reporting. Data collected for periodic general reporting can be used to maintain interest and keep the public properly informed about a community's experiences with problems related to alcohol availability.

- Maintain close ties with State ABC's and alcohol and drug programs. Close cooperation with State ABC agencies offers a number of benefits for local jurisdictions. Nearly all State ABC's depend heavily on participation by local jurisdictions in State licensing and enforcement activities, and they often respond well to the concerns of local police and planning departments. Overextended ABC staff often find it easier to work more closely with local agencies that know the State's procedures and policies for approving or disapproving outlets, imposing conditions on licenses, and helping with enforcement activities. Staff from local police and planning departments who understand the full range of issues regarding their communities' alcohol outlets thus should be designated as "alcohol outlet specialists" who can be readily contacted by the State ABC. As things stand now, most city agencies have little contact with alcohol-related single State agencies or, in larger States, with county or regional programs. Closer working relationships can be forged if cities develop their own capacities to collect and manage data on alcohol problems and take more active roles in the prevention of availability-related problems. City agencies also can go directly to SSAs or county and regional programs to seek funding to support community alcohol prevention programs.

- Spread the word. Local public agencies are also responsible for getting community groups and alcohol retailers to be concerned about alcohol-related problems and for arousing community members to participate in prevention activities. Municipalities should thus facilitate coordination among officials, concerned community groups, alcohol retailers, and other sectors of the community to raise local awareness of alcohol-related problems.

- Help alcohol outlet owners and managers. Help for outlets in complying with local policies for managing problems related to alcohol availability can be provided in the following ways:
  1. Clarify standard review procedures for new alcohol license applications. This can be done by developing a clear and precise presentation of local legislation and regulations and following it up with administrative instructions and guidelines spelling out community procedures for reviewing applications from alcohol outlets.
  2. Publish a summary of local policies that facilitate implementation and monitoring. This document should be a reader-friendly, step-by-step summary of the procedures that retailers need to follow and that community groups can use to monitor outlets for implementation and enforcement of local policies.
  3. Provide agency staff to serve as direct contacts with the public. Local officials should collaborate with community organizations and retailers to train public agency staff who can explain both old and new procedures and walk them through the steps that need to be followed.
  4. Hold preapplication and preenforcement meetings. Local police and planning departments can meet with retailers preparing to apply for licenses to explain the steps in the approval process and to resolve any issues related to the design and operation of the proposed outlets. Preenforcement, or warning, meetings are similarly useful to offer outlet operators the opportunity to correct potential problems on their own or to accept help before official action is taken (Wittman 1992; Wittman and Hudson 1995).
  5. Encourage responsiveness, promptness, and efficiency. License and permit processes can be useful tools for preventing alcohol-related problems. It should go without saying that efforts to protect public health and safety must be administered with responsiveness, promptness, and efficiency. Implementation of local alcohol availability policies should therefore allow creative modifications to standard review procedures to eliminate elements that have little preventive value or that can be accomplished more expeditiously by other means.
    - Make use of the "consent calendar" included in most review processes to permit rapid approval of noncontroversial, nonproblematic permits and licenses.
    - Simplify the review process for low-risk outlets. For generally low-risk outlets - such as full-service restaurants - a hearing examiner alone should be allowed to review applications, provided that a full review board or panel is available for appeals.
    - Provide economic incentives for retailers. Many alcohol retailers share community concerns about alcohol-related problems and may welcome assistance from the city to improve their businesses in ways that lessen dependence on alcohol sales. For example, cities sometimes offer grants or very low-interest loans for remodeling stores, providing RBS training, obtaining credit or other financial incentives, and shifting sales from alcohol to other retail items or services.

- Respond promptly and effectively to community concerns about availability-related problems and encourage active participation by local groups and organizations in community management of alcohol availability. The effectiveness of local alcohol-related policies depends on the active efforts of concerned local groups. When community oversight of alcohol outlets drops off, the problems that inevitably result are less likely to receive attention in a timely or effective manner. Local public agencies can maintain high levels of community participation in the following ways:
  1. Keep the public informed by providing information about alcohol-related problems in the community in user-friendly ways that respond to people's concerns. For example, municipalities can provide periodic reports on alcohol availability issues to be used as a general reference by all stakeholders. In addition, once such an information system is developed, local police and planning departments can provide information on request describing the problems in the local contexts of time, location, settings, costs, the number and types of people affected, and responses to the problems.
  2. Make effective use of local news media. Media advocacy techniques can be used by all stakeholders, including public officials and community groups, to build support for preventive alcohol policies (Wallack et al. 1993). With the advent of local Internet access and the development of a community-level GIS, interested parties can log on to get the information for themselves.
  3. Provide a community complaint line. Complaints should be easy to make or file, yet detailed enough to serve as the basis for a response. Details that should be clearly identified include type of problem, time, location, participants, and relationship to the alcohol outlets in question. Each new complaint should be entered into the community's database on alcohol problems and alcohol availability.
  4. Respond promptly to problems. Community groups often identify the promptness of responses by public officials to identified problems as a major factor in satisfaction with local government. Immediate acknowledgment of such problems and followup are equally important.
  5. Use municipal resources to encourage participation in community-wide prevention activities. Visible support by prominent public officials reinforces a community's commitment to local prevention campaigns. For example, endorsements by leading public figures, collateral policies to reduce risks at points of sale and points of consumption, and added enforcement time for local government staff have all been used to influence public perceptions and public responses to antidrunk-driving campaigns.
  6. Provide prompt and fair enforcement. Enforcement is a critical feature of any local policy. Alcohol retailers, their staff, and patrons frequently test the limits of preventive policies on alcohol availability. Although only a small fraction of patrons and operators are involved, no retail setting is free of the potential for such problems. Both the perception and the actual execution of prompt and effective enforcement are necessary to minimize noncompliance with local availability policies.
    - Coordinate responses to problems. Both police and local community groups must be able to identify alcohol availability problems as they occur and properly document them at that time. Local groups such as unhappy patrons of an establishment, residential neighbors, or other businesses and community organizations familiar with an outlet in question are the key to reporting the sorts of problems most likely to be missed by routine police patrols.
    - Negotiate mitigation before taking enforcement actions. If enforcement clearly includes the threat of losing an ABC license or local alcohol permit, retailers are more likely to be compliant, or at least more willing to sell the outlet or license rather than lose everything. When convinced of the value of mitigation, many alcohol retailers are prepared to make adjustments to their operations to reduce the incidence of problems associated with their outlets.
    - Impose sanctions promptly and firmly when required. If noncompliance is both persistent and well documented, a locality should act at once to suspend or revoke an outlet's retail alcohol license through the State ABC and to suspend or revoke its use permit through local planning and zoning enforcement procedures.
  7. Facilitate contacts with other stakeholders. Local public agencies are well positioned to work with insurance companies, national owners of chain outlets, investors, noteholders, and other interested parties. Municipalities can take the lead in informing these parties of a community's alcohol availability policies, and can arrange introductions with community groups and retailers to stimulate activities aimed at reducing risks and preventing problems. For example, city officials can inform a large chain interested in opening a restaurant of local operating requirements and physical design standards for the safe service of alcoholic beverages, and can arrange introductions with neighbors and other businesses concerned about the restaurant's potential impact on a neighborhood.

### Local Funding for Community Management of Alcohol Availability

Nearly all cities and counties have the capacity to dedicate the resources needed to implement local alcohol availability policies. The real question is how best to exercise this capacity: Should communities (1) absorb the costs of administration as a public investment in lower problem rates, which will probably result in lower public agency costs and the intangible benefits of fewer troubles to worry about, or (2) charge fees or levy taxes to defray public agency costs for reviewing and monitoring alcohol availability?

#### Integrating Costs Into General Management Funds

For the most part, local management procedures can be carried out by a city or county's planning and police departments, provided the locality is already involved in the administration of CUPs, special-use permits for sensitive land uses, and special events. Localities in which CUPs and special-permit review processes are already widely used for other purposes may view increased attention to alcohol availability as a modest shift in priorities rather than as a new direction requiring substantial increases in staff.

If new policies on alcohol availability are leading the way in a community's use of more active application and enforcement procedures, or if a community is considerably strengthening its local availability policy, additional city or county public agency staff may be called for. A rationale can be made for absorbing the costs of such administration as a general fund item as follows:

- Additional resources to manage alcohol availability may be offset by decreases in costs associated with availability-related problems such as crime requiring police services.
- Alcohol availability issues such as young people's easy access to alcoholic beverages in retail outlets involve basic community values.
- Accepting the costs of administration as a general fund item signals that a local policy to prevent alcohol availability-related problems reflects a central community concern, the costs of which can be spread across the board.

Alternatively, local legislatures may choose to absorb the costs of administration initially on a trial basis to see whether the availability-management policies produce the desired results at bearable expense. If not, increased fees can be established at the close of the trial period.

Municipalities may decide to impose all or some of the costs of administering alcohol availability policies on alcohol outlets. Examples of other sources of continuing funds that might be considered include modest fee increases paid by all businesses for business permits and related city services, grants from appropriate State and Federal sources, and property and sales taxes.

#### Levying Special Fees to Manage Alcohol Availability Costs

Nearly all localities have the power to levy fees for their services, and some jurisdictions can impose taxes to pay the costs of administering the local management process. As the values and actual costs of implementing a policy become clear, communities can decide how best to use their own powers to carry the costs of the local availability policy. In California, for example, local planning and zoning departments' charges range from less than $100 to more than $3,000 for performing a planning and zoning review, depending on the requirements of local ordinances, the complexity of the review required, and other cost factors.

A four-city demonstration study of community-based prevention planning strategies calculated the costs for a community organizer dedicated to environmental prevention approaches at about 50 cents per resident per year (about $50,000 for a city of 100,000). This calculation assumed the following:

- A State substance abuse agency offered technical assistance with prevention methods.
- In-kind office support, staff, and secretarial assistance were available from a city, county, or other host organization.
- The local program was able to call on backup from a university with a research program on alcohol-related problem prevention.
- The State ABC agency was responsive.

Under such a supported arrangement, over a 5-year period the community organizer in one demonstration community was instrumental in stimulating the city to develop the following:

- A city policy disallowing alcohol use at family parks and community street fairs.
- A CUP ordinance for alcohol outlets.
- A responsible beverage service policy for a regional arts center.
- Partnerships between landlords and the city aimed at preventing substance abuse problems in high-risk apartment complexes.

The costs for administrating these policies were absorbed into the city's current staff structure and permit fee schedule.

This model suggests that an integrated approach to bolstering city or county prevention resources can result in the cost-efficient development of prevention policies and programs at the community level. With strong support from a university-based prevention research program, State substance abuse and ABC agencies, and a county alcohol program agency, many localities have the opportunity to develop several mutually reinforcing availability management policies at relatively modest cost. Of course, although this approach can keep costs down for a city or county, it requires considerable coordination with universities and State agencies (Wittman and Biderman 1992).

## Step 4 - Institutionalizing Policies: Continuation

Institutionalization is the process of incorporating provisional policies into the routine operations of an agency or organization. Once preventive policies on alcohol availability have been fully adopted and have produced useful results, they are likely to gain acceptance as part of an organization's operations. On the other hand, failure to diligently implement a local availability policy can damage the credibility of the policy itself, even though it might have worked well if implemented as designed or with more vigor. As a policy becomes an integral part of an agency or organization, it becomes less susceptible to change caused by outside pressures and challenges from its detractors. At the same time, however, the policy also becomes open to the dulling effects of bureaucracy, which can cause what was once fresh and powerful to lose its force and effectiveness over time. Furthermore, after a policy is successfully implemented and several years pass, people may lose sight of the policy's preventive value and begin to wonder why the community should bother maintaining extensive oversight when no serious problems seem to be present. For all these reasons, someone needs to keep careful watch over the alcohol availability policies adopted by a jurisdiction so that their record of success and preventive purpose is continually fresh in the minds of decisionmakers.

### Keeping the Process Dynamic

Alcohol availability policies should not be static, but should be continually reviewed to assess whether they address the availability-related problems they were intended to solve. Policies should also be responsive to changing demographics and shifting business climates in the area they cover. Prevention practitioners thus should periodically assess how these changes affect the efficacy of adopted alcohol availability policies.

To do so, it is important to continue collecting data on local alcohol-related problems and outlets in order to support planning, implementation, monitoring, and the improvement of policies. It also helps to keep track of the actions of agencies and organizations that maintain ongoing involvement in local management issues.

### Establishing a Public Review Process for Alcohol Availability Policies

Considerations and discussions regarding alcohol availability can create political and community controversy. Without a well-established public review process already in place within a jurisdiction, opening a policy up to revision may invite some groups and individuals to attempt to weaken or even scuttle the policy, claiming that it is unworkable.

Using the following questions to conduct periodic policy reviews can help maintain the desired positive attitude:

- Is local management responsive to the observed problems with alcohol availability? Is information about availability-related problems routinely reported and analyzed for its significance to prevention initiatives and for monitoring outlet performance? Does the system for collecting information about alcohol problems report those problems within their community contexts so that local management can properly assess them? If there are discrepancies between community-based complaints about outlets and official records of those problems, does local management investigate and resolve those discrepancies?
- Is the policy fairly, uniformly, and appropriately applied? Are the alcohol availability policies administered to address real problems that have been clearly documented? Are they applied in a nondiscriminatory manner? For example, is a CUP being used inappropriately to harass retail outlets, or is an ordinance prohibiting alcohol use in public parks being used to keep homeless individuals out of parks when there is no evidence of public drinking? If so, both the policy's design and its implementation require examination.
- Is the policy easy to administer? Does operating experience show that the policy is unnecessarily difficult to implement as originally adopted? Does the policy not function as intended? Have there been changes in operating conditions and personnel in local organizations and government bodies that make the policy difficult to administer? Is the search for improvements in policy administration continuous? Are modifications to the policy always welcome when they improve the ease of administration without loss of policy force or effectiveness?
- Does the policy use recent research findings regarding the link between public health and safety problems and alcohol availability? Are policymakers aware that public health researchers continue to discover new relationships between alcohol availability and community problems? Do findings from this research continue to be used in local policy making activities? Does the research serve as one starting point for continuing examination of policies currently in place? Are locally collected data on the distribution of alcohol-related problems and alcohol outlets used to explore and verify findings from experimental research and from prevention efforts in other communities? Has the planning group provided an appropriate place to house this ongoing review of the research as it applies to local alcohol policy?
- Does the policy review process include community feedback? Is there an informed and active community to consult on the operations of the community's alcohol policies? Does the review board consult it? Has vigorous organizing and community-level planning occurred among a cross-section of public agencies and organizations in the community? Are local organizations and private citizens able to speak clearly and convincingly about the impact of availability policies on the community's availability-related problems?
- Do administrators of an alcohol availability policy make periodic reports to the community? Does the city manager, for example, make annual or biannual reports to the city council, and are community members encouraged to attend these meetings? Do these reports describe current progress and outstanding issues surrounding the community's policies for preventing problems associated with alcohol availability? Do these reports provide an opportunity for the entire community - public agencies, community organizations, the retail community, ad hoc groups such as neighborhood associations, and concerned citizens - to assess the extent of alcohol availability-related problems in the community and the effectiveness of the current management? Are community comments, suggestions, and recommendations given serious consideration?

Most communities can put together successful organizations that both represent all elements of the community and focus the energy and imagination unique to a community that has discovered its own power to effect change. Such communities can work together to adopt the environmental planning process described in this chapter, using the recommended prevention interventions to develop and implement policies that effectively address problems related to alcohol availability in their communities.

## Considerations and Strategies for Evaluation

Alcohol-related prevention efforts do not end when a policy, law, or program goes into effect. It is thus essential to assess whether a strategy or policy was properly implemented and whether it accomplished its intended goals.

Answering these concerns involves two separate planning activities: documentation and evaluation. A community organization or its planning group thus needs to take care in planning for documentation and evaluation from the very beginning of its efforts. Decisions to be made include what information will be collected (documentation) and how it will be used in both process and outcome evaluations.

Documentation entails collecting data according to a designed protocol, keeping records, and observing or monitoring. Community workers need to collect data throughout the planning and implementation processes. They must collect baseline data on the community before intervention, data on implementation of the intervention process itself, and data on the end results. These data will be used to (1) identify problems; (2) set the stage for planning and developing prevention activities; (3) provide information needed to guide midcourse adjustments; and (4) provide information needed to evaluate the performance and impact of the prevention activities as well as mid-course adjustments.

The central purpose of evaluation is to take information provided by the documentation process and use it to assess the effects of policies, regulations, and procedures, including the impacts of prevention activities, programs, and strategies.

outcome evaluation - an analysis that focuses research questions on assessing the effects of interventions on intended outcomes.

### Seeking Assistance With Evaluations

Many community organizers are intimidated by the need to evaluate their activities' progress. They may believe they do not have the resources, time, or expertise to conduct evaluations. Others may feel that evaluations are useless or fear that the results will be harmful in some way to the morale of participants or funding sources. As a result, practitioners often lose the opportunity to gain objective information about the success of their undertakings.

With some careful thought and consultant expertise, however, it is possible to design evaluations that will yield information about implementation of an intervention and its impact or outcome. Many organizations have access to an expert who can be consulted on the planning and design of an evaluation. Universities, colleges, and community college systems often have departments with this expertise. Well-conducted evaluations can yield even more information for a community when it pools its findings with those of others; the community learns more about what works and how to go about making effective changes.

### Considering the Reasons for Documentation and Evaluation

The reasons for documentation and evaluation vary according to each situation. It is, however, most important to document and evaluate new interventions designed to prevent alcohol-related problems. The following six reasons are common to most efforts to manage alcohol availability:

1. To better understand the associations between retail alcohol sales and alcohol-related problems. In assessing cross-sectional and temporal trends, epidemiological studies may explore factors such as outlet density, rates of alcohol consumption per adult, and alcohol-related problems such as drinking and driving, crime and safety issues, and public drunkenness.
2. To justify, plan, and develop prevention programming. Information can be gathered on alcohol availability issues such as outlet density and capacity; licensing and enforcement practices; land-use arrangements, zoning, and regulations; interactions between State and local authorities and management; and community retailing environments.
3. To facilitate policy administration. An alcohol retail system may be monitored (a form of process evaluation) to determine whether it is being administered according to plan and whether its arrangements and procedures are appropriate for the community.
4. To evaluate the impacts of policies or programs. Studies employing pre- and posttest and time-series designs may be conducted to evaluate the effects of specific prevention activities. Such studies can measure alcohol-related problems and consumption before and after implementing a policy and can measure whether the policy achieved the intended effects. These studies require a comparison group if practitioners wish to say with certainty that the change resulted from the intervention and not some other factor.
5. To guide midcourse adjustments in prevention programming. The study or monitoring of some of the areas described above can be used to refine and modify prevention programs or policies that are already under way.
6. To interpret changes over time in retail system arrangements, the role of prevention activities, and secular trends. Activities such as building coalitions and identifying problems can be documented and evaluated to determine ways in which prevention efforts and prevailing popular trends affect alcohol availability policies and procedures over time.

random assignment - the process through which members of a pool of eligible study participants are assigned to either an intervention group or a control group on a random basis, such as through the use of a table of random numbers.

### Matching Evaluation Designs to Needs

Community organizations may wish to consider several nonexperimental evaluation designs that may prove feasible in terms of time and expense. Such designs lack the rigor of experimental designs, which involve random selection and assignment of participants to intervention and control groups, or of quasi-experimental designs, which involve carefully structured comparisons. Nonexperimental designs may, however, better fit the needs and available resources of local efforts, as follows:

- Cross-sectional evaluation designs compare outlet densities and rates of alcohol-related problems in a given area. This method can be used to establish the relationship between alcohol availability and alcohol problems, but cannot establish cause-and-effect relationships.
- Pretest/posttest evaluation designs can measure alcohol-related problems and consumption before and after implementing a new policy and can measure whether the policy achieved intended effects. Without a comparison group, however, it cannot be said with certainty that a change resulted from an intervention and not some other factor. But pretest/posttest studies can provide simple cause-and-effect suggestions.
- Time-series pretest/posttest designs involve a group that is tested more than once before a new policy is implemented and retested more than once after the policy is implemented. Although these studies are more costly than other nonexperimental designs, they provide greater confidence that the changes noted result from the policy change and that the documented measures are reliable.
- Natural study designs use both planned and unplanned changes in an environment that, while not the direct result of a prevention intervention, have an impact on alcohol availability. For example, the 1992 civil unrest in Los Angeles destroyed some 400 retail alcohol outlets (see appendix E); a natural study design could examine the effects of this unplanned sudden decrease in outlets. Planned natural experiments can also be evaluated for their impacts on consumption and alcohol-related problems. An example of a planned natural experiment would be a State's decision to eliminate its monopoly on retail alcohol sales in favor of allowing licensed retail sales. If evaluators can respond quickly enough to such a natural opportunity for study, it may be possible to collect data both before and after such policy changes take place.

### Identifying Sources of Data for Analysis

Prevention planners should begin by making an overview of the data readily available and a list of the additional data they will need. Baseline data describe a starting point; process data will tell the community whether and how changes have occurred since prevention intervention was initiated. Outcome data define the measurable or describable effects the policies or prevention interventions have had. Both process and outcome measures are appropriate evaluation tools, but neither are possible without reliable data.

Communities have a number of obvious and not-so-obvious sources of data that can be used for evaluation. For example, existing data from a community may be used to document the extent of its problems. Special arrangements may be needed to collect data for process assessment and outcome evaluation. Data collection sources that can be used in studies of alcohol availability include the following:

- Archival statistics on alcohol sales, drinking-related problems, and numbers and types of outlets.
- Articles or interviews with experts on alcohol availability.
- Contacts with other local agencies and organizations doing work in this area.
- Discussions with State and Federal agencies regarding the experiences of model projects elsewhere.
- Interview and questionnaire responses obtained from patrons, servers, and the general public.
- Legal, bureaucratic, and regulatory documents.
- Literature reviews regarding alcohol availability and its impact on public health and safety.
- Newspaper coverage of drunk driving arrests and of accidents and violence related to alcohol use.
- Obtrusive and unobtrusive community observations such as visual assessments of neighborhood conditions and activities near or in licensed alcohol outlets.
- Official data from public agencies, such as reports from local authorities that include special tabulations by officials or agencies of their contacts or activities.
- Public and media reactions to alcohol availability issues.
- Reports from community monitors set up by an intervention program.
- Special data collected by law enforcement officers and others concerned with alcohol-related problems in a community.
- State ABC's and SSAs.

### Making Arrangements for Data Collection

Although data collection can be a tedious and time-consuming process, it is not without its rewards. Once a planning group has defined what data it needs and has set up appropriate record keeping forms, a well-organized community organization should be able to recruit and train a corps of volunteers to collect and record the data.

Data collecting in and of itself is a form of community organizing in that it involves establishing relationships that can be called upon later if needed. What's more, those who collect the data become more and more convinced by it of the need for change, and come up with new ideas through their reviews. Individuals' commitment to developing good plans and following through with dedicated action grows stronger as workers get more involved in defining the problems.

The importance of establishing a strong and satisfying process for collecting reliable data cannot be overstressed. It requires skilled community workers to artfully blend the requests of planners, the workloads of data collectors, the curiosity of analysts, and the impatience of report writers and presenters. The final product, their findings, becomes a vehicle for educating and enlisting the support needed to get a project off the ground.

As workers go about the data collection process, some will become interested in being process monitors or will identify others who might effectively serve as monitors. Monitors, like data collectors, must be recruited, trained, and supported. Some monitors might be staff assigned from agencies involved in the intervention; others will come from the community.

### Data Reporting Partners and Sharing Credit and Ownership

Data collection and reporting can be enhanced by partnership arrangements between parties with somewhat different orientations in the area. For instance, prevention organizations may wish to set up partnership arrangements with specific researchers, evaluation groups, or organizations. Alternatively, researchers may initiate plans to evaluate a new or ongoing prevention activity. In either case, professional groups or individuals need to develop an effective working arrangement. Issues of ownership, sharing of credit, arrangements for data reporting, and control over interpretations are central to any such arrangement. Therefore, those directly involved may wish to develop a joint letter of understanding clarifying any agreements that have been reached in these areas.

Any of a number of possible systems can be developed for acknowledging the reporting partners in such arrangements. For example, for confidential interviews with the general public or key informants who do not wish to be publicly identified, a general acknowledgment of the group or collective might be appropriate. In other instances, the key people and agencies providing access to the data should be acknowledged for their contributions. If they play a role in writing a published report on a project, for example, they should be offered authorship credit.

Arrangements for data collection and analysis can become somewhat more complicated if the agency providing the data also requests the right to final approval or veto of their presentation and interpretation. In some instances, an agency may also request control over how, to whom, and in what form the results are disseminated. In principle, these types of arrangements can be a major complication for a successful evaluation.

A preferred solution is to make up-front arrangements for the interested parties to review and comment on draft reports and to negotiate agreement on the interpretations. It should be understood that those designing an evaluation, conducting its analysis, and interpreting its data have the final word on any public product. Although such an arrangement may work in practice in many instances, in some cases both the interpretation and the right to report it may be called into question.

### Competing Interpretations of Data Analysis

Competing interpretations of data about alcohol availability may arise, either within a study group itself or between those conducting the analysis and other interested parties. There are rarely simple ways to handle these situations. If the differences in interpretations arose within a project group, it may be feasible to offer alternative interpretations of the results within the report. Offering alternative explanations is clearly desirable because a more open-minded stance on possible outcomes of evaluation can stimulate broader-based planning for future prevention activities.

If concerns about data interpretation originate from outside a project group, then the procedures for presenting alternative interpretations may be more complicated. One possibility is to give key potential critics an opportunity to review a draft of the report and then to incorporate those of their comments considered valid by the authors.

### General Recommendations for Evaluations

At the outset of a prevention planning or evaluation process, the key players should devote a substantial amount of time to outlining in detail the purposes, key questions, and objectives of the undertaking. Planners also should set up protocols for data collecting; focusing on what information is most critical will help avoid the pitfall of designing an evaluation around whatever data are already available rather than what information is needed.

data analysis - the process of examining systematically collected information.

Whenever possible, it is a good idea to use several data collection methods in combination. To provide a broader database, if feasible prevention workers should use both direct information, such as that collected from interviews and observations, and indirect information, such as archival statistics on alcohol sales and police interventions.

Great attention should also be paid to the scope, coverage, validity, and reliability of the data. It is therefore important to know how the data are collected, stored, and organized, as well as whether any changes have been made over time in the protocols for data collection that might affect the quality or comparability of the data.

It is best to set up a routine system for the collection of key data to inform planning and evaluation. This process can significantly enhance or facilitate not just one, but multiple projects. Setting up a routine system for data collection is an effective use of resources and makes it possible to use the same data for more than one project.

## Conclusion

Solving problems related to the availability of alcohol at the community level can be an uphill struggle. Prevention practitioners face many challenges to their efforts to facilitate the development of strong community-based programs. But even though this process has never been easy, it has always proved exciting, surprising, and empowering for those bold enough to attempt it.

In this guide, prevention practitioners are asked to make a major change in the way they look at and manage the control of alcohol-related problems in their communities. Practitioners are challenged to shift their focus from individual cases and problem individuals to broader changes in alcohol availability policies that will have a long-term impact. Successful development of local policies depends on linking availability-related problems to the interests of the individuals or groups most directly affected by the problems: the stakeholders. This new approach - the environmental prevention method - is already in wide use and has demonstrated to be an effective community tool for the management of alcohol availability. This community-based approach, the Four-Step Plan, and the evaluation strategies presented in this chapter are packed with ideas for various prevention activities rather than for any one narrow plan that must be followed. Within this broad framework of possibilities, practitioners in every community should be able to find enough information and latitude to develop policies and practices that will work where they live.

## References

Alinsky, S. D Rules for radicals: A pragmatic primer for realistic radicals , New York: . Random House.
Bobo, K., Kendall, J., & Max, S Organizing for social change , Washington, DC: Seven Locks Press.
City of Euclid v. Ambler Realty Co. 272 U.S. 365, 47 S. Ct. 114 (1926): 19, 44, 69, 75, 85.
Florence Dolan v. City of Tigard. U.S. Supreme Court on Writ of Certiorari to Supreme Court of Oregon. 1994.;No. 93-518.
Harding, J. R., & Wittman, F. D GIS boosts drug prevention planningGIS World, 8(6) 80 83
Lofquist, W. A The technology of prevention workbook , Tucson, , AZ: . Associates for Youth Development, Inc
Marcus, N., & Groves, M. W The new zoning: Legal, administrative, and economic concepts and techniques In Praeger special studies in U.S. economic and social development, New York: . Praeger.
Wallack, L., Dorfman, L., Jernigan, D., & Themba, M Media advocacy and public health: Power for prevention , Newbury Park, , CA: . Sage Publications.
Wittman, F. D. Issues in controlling alcohol availability. In Western City Magazine (Sacramento: League of California Cities), 9--13.
Wittman, F. D Community planning to prevent problems related to alcohol availability: Observations on the use and effectiveness of an environmental approach, Berkeley: University of California, Institute for the Study of Social Change.
Wittman, F. D An overview of the development and use of conditional-use permits to prevent problems related to alcohol outletsCalifornia Department of Alcohol and Drug Programs. , Berkeley: University of California, Institute for the Study of Social Change.
Wittman, F. D Local control to prevent problems of alcohol availability: Experiences in California communities In M. Plant, E. Single, & T. Stockwell (Eds.), Alcohol: Minimizing the harm (pp. 43 71), London:
Wittman, F. D., & Biderman, F The California Community Planning Demonstration Project: Experiences of planning for prevention in four municipalities Experiences with community action projects: New research in the prevention of alcohol and other drug problems (CSAP Prevention Monograph 14 pp. 102 114), Rockville, , MD: . Center for Substance Abuse Prevention.
Wittman, F. D., & Harding, J. R The Hayward ASIPS project: Design and use of a community-based information planning system to prevent alcohol and other drug problems (revised), Berkeley, , CA: . CLEW Associates.
Wittman, F. D., & Harding, J. R ASIPS/GIS Community Tour, City of Berkeley (Alcohol/drug sensitive information planning system in a Geographic Information System format), Berkeley, , CA: . CLEW Associates.
Wittman, F. D., Harding, J. R., & Sparks, M. ASIPS/GIS program manual. (prepared for the Robert Wood Johnson Foundation). Berkeley, CA: CLEW Associates.
Wittman, F. D., & Hudson, M Local initiatives to prevent problems related to alcohol availability: Notes from three communities, Berkeley: University of California, Institute for the Study of Social Change, Community Prevention Planning Demonstration Project
Wittman, F. D., & Wright, A. Viewpoint: The three actor model. Prevention Pipeline. 35-36.
Zander, A Effective social action by community groups , San Francisco: Jossey-Bass.

## References

Adrian, M., Ferguson, B. S., & Her, M Does liberalizing access to alcohol result in increases in alcohol consumption? The case of wine in Quèbec, Toronto, , Ontario: Alcoholism and Drug Addiction Research Foundation.
Aguirre-Molina, M Communities take charge! A resource directory for the prevention of alcohol and other drug problems among youth , Piscataway, , NJ: . University of Medicine and Dentistry of New Jersey/Robert Wood Johnson Medical School, Department of Environmental and Community Medicine
Ames, G. Research and strategies for primary prevention of workplace alcohol problems. Alcohol Health and Research World. 17(1):19-27.
Beauchamp, D. E Beyond alcoholism: alcohol and public health policy , Philadelphia: Temple University Press.
Bernard, B., Fafoglia, B., & Perone, J Knowing what to do - and not to do - reinvigorates drug education In J. K. Van de Kamp (Ed.), Schools and drugs: A guide to drug and alcohol abuse prevention curricula and programs, Sacramento, , CA: . Office of the Attorney General
Blomberg, R. D Lower BAC limits for youth: Evaluation of the Maryland .02 law (DOT Pub. No. HS 807 860), Washington, DC: U.S. Department of Transportation, National Highway Traffic Safety Administration.
Blum, H Planning for health , New York: . Human Sciences Press.
Calhoun, S., & Colman, V Alcohol availability and alcohol-related problems in Santa Clara County , San Jose, , CA: . County of Santa Clara Health Department, Bureau of Alcohol Services.
Campbell, K. E., Stinson, F. S., Zobeck, T. S., & Bertolucci, D Trends in alcohol-related fatal traffic crashes, United States, 1977--94 (Surveillance Report No. 38), Bethesda, , MD: . National Institute on Alcohol Abuse and Alcoholism.
Cassady, D., Flora, J., & Foote, D Increasing community involvement in alcohol licensing: How to work with the Alcoholic Beverage Control (ABC) , San Diego, , CA: . County of San Diego Department of Health Services.
Cassady, D., Flora, J., & Foote, D Server Intervention: Encouraging responsible alcoholic beverage sales and service, San Diego, , CA: . County of San Diego Department of Health Services.
Casswell, S., Stewart, L., & Duignan, P. The negotiation of New Zealand alcohol policy in a decade of stabilized consumption and political change: The role of research. Addiction. 88(Suppl.):9S-17S. [pmid: 8453350].
Center for Substance Abuse Prevention. (1993). National Prevention System: Regional meeting guideline. Rockville, MD: Author.
Constitution of the United States of America: Analysis and Interpretation. (1973)., Washington, DC: U.S. Government Printing Office
Cook, P. J., & Moore, M. J. Violence reduction through restrictions on alcohol availability. Alcohol Health and Research World. 17(2):151-156.
Delewski, C., Saltz, R. F., & Mosher, J. F. Evaluation of a community-based server intervention program. (Performer: Trauma Center, San Francisco General Hospital. Funder: Division of Injury Control, Centers for Disease Control, Atlanta).
De Pape, D., Gliksman, L., & McCarty, T Harm reduction: Municipal sites Abstracts from the 10th International Alcohol Policy Conference, Ontario, Canada.
Ditman, D. L. Controlling alcohol availability to youth: A survey of alcohol sales establishments. Journal. 2:281-286.
Dull, R. T., & Giacopassi, D. J. An assessment of the effects of alcohol ordinances on selected behaviors and conditions. Journal of Drug Issues. 16(4):511-521.
Dull, T., & Giacopassi, D. J. Dry, damp, and wet: Correlates and presumed consequences of local alcohol ordinances. American Journal of Drug and Alcohol Abuse. 14(4):499-514.
Fillmore, K. M., & Wittman, F. D. The effects of availability of alcohol on college student drinking: A trend study. Contemporary Drug Problems. 11(3):455-492.
Fitzgerald, J. L., & Mulford, H. A. Consequences of increasing alcohol availability: The Iowa experience revisited. British Journal of Addiction. 87(2):267-274. [pmid: 1555003].
Fitzgerald, J. L., & Mulford, H. A. Alcohol availability, drinking contexts, and drinking problems: The Iowa experience. Journal of Studies on Alcohol. 54(3):320-325. [pmid: 8487541].
Fontaine, R. A. DUI pre-arrest alcohol purchases: A survey of Sonoma County drunk drivers. Journal of Studies on Alcohol. 53(4):345-348. [pmid: 1466667].
Forster, J. L., McGovern, P. G., Wagenaar, A. C., Wolfson, M. Perry, C. L., & Anstine, P. S. The ability of young people to purchase alcohol without age identification in northeastern Minnesota. Addiction. 89(6):699-705. [pmid: 8069171].
Forster, J. L., Murray, D. M., Wolfson, M., & Wagenaar, A. C. Commercial availability of alcohol to young people: Results of alcohol purchase attempts. Preventive Medicine. 24:342-347. [pmid: 7479623].
Freire, P Pedagogy of the oppressed , New York: . Continuum Publishing Corp.
Gibbs, J., & Bennett, S Together we can reduce the risks of alcohol and drug abuse among youth: A framework for community prevention planning , Seattle, , WA: . Comprehensive Health Education Foundation.
Gliksman, L., McKenzie, D., Single, E., Douglas, R., Brunet, S., & Moffatt, K. The role of alcohol providers in prevention: An evaluation of a server intervention programme. Addiction. 88(9):1195-1203. [pmid: 8241919].
Godfrey, C. Natural experiments with decreased availability of alcoholic beverages: Finnish alcohol strikes in 1972 and 1985. Addictions. 1088(5):700-701.
Gruenewald, P. J Alcohol problems and the control of availability: Theoretical and empirical issues Economics and the prevention of alcohol-related problems (NIAAA Research Monograph 25, DHHS Pub. No. NIH 93-3513, pp. 59--90), Washington, DC: U.S. Government Printing Office
Gruenewald P. J., Madden P., & Janes, K. Alcohol availability and the formal power and resources of state alcohol beverage control agencies. Alcoholism Clinical and Experimental Research. 16(3):591-597.
Gruenewald, P. J., Millar, A. B., & Treno, A. J. Alcohol availability and the ecology of drinking behavior: An ecological model of alcohol use and abuse. Alcohol Health and Research World. 17(1).
Gruenewald, P. J., & Ponicki, W. R The relationship of outlet densities and alcohol sales to alcohol-related traffic crashes , Berkeley, , CA: . Prevention Research Center.
Gruenewald, P. J., Ponicki, W. R., & Holder, H. D. The relationship of outlet densities to alcohol consumption: A time-series cross-sectional analysis. Alcoholism Clinical and Experimental Research. 17(1):38-47.
Hawkins, J., Arthur, M., & Catalano, R Preventing substance abuse In M. Tonry & D. Farrington (Eds.), Building a safer society: Strategic approaches to crime prevention (Vol. 19 pp. 343 427), Chicago: University of Chicago Press.
Hennessy, M. Designing and evaluating alcohol problem community interventions: Quasi-lessons from the experience of medical trials. Journal of Primary Prevention. 11(3):169-192.
Holder, H. D. Community prevention: A systems perspective for alcohol abuse. Psychiatric Annals. 14(8):589-594.
Holder, H. D. A review of research opportunities and issues in the regulation of alcohol availability. Contemporary Drug Problems. 15(1):47-66.
Holder, H. D. Prevention of alcohol-related problems. Alcohol Health and Research World. 13(4).
Holder, H. D. RI alcohol-related injury program shows promise. Alcoholism Report. 17(8).
Holder, H. D Alcohol policy and the reduction of alcohol problems Paper presented at the 36th International Institute on the Prevention and Treatment of Alcoholism, Stockholm, Sweden.
Holder, H. D Alcohol availability and accessibility as part of the puzzle: Thoughts on alcohol problems and young people Paper presented at the Working Group on High-Risk Youth, Washington, DC.
Holder, H. D Prevention of alcohol-involved traffic crashes: Research implications of alcohol accessibility, price, and mass communications , Berkeley, , CA: . Prevention Research Center.
Holder, H. D. Changes in access to and availability of alcohol in the United States: Research and policy implications. Addiction. 88(Suppl.):67S-74S. [pmid: 8453347].
Holder, H. D., and Stoil, M. J. Beyond prohibition: The public health approach to prevention. Alcohol Health and Research World. 12(4):292-297. [pmid: 10314325].
Holder, H. D., & Wagenaar, A. C. Effects of the elimination of a state monopoly on distilled spirits retail sales: A time-series analysis of Iowa. British Journal of Addiction. 85(12):1615-1625. [pmid: 2289062].
Holder, H., & Wagenaar, A. C. Mandated server training and reduced alcohol-involved traffic crashes: A time-series analysis of the Oregon experience. Accident Analysis and Prevention. 26(1):89-97. [pmid: 8110360].
Howard, J. Alcohol prevention research: Concepts, phases, and tasks at hand. Alcohol Health and Research World. 17(1):5-11.
Janes, C. R., & Ames, G. M The workplace In M. Galanter (Ed.), Recent developments in alcoholism: Vol. 2. Ten Years of Progress (pp. 123 141), New York: . Plenum Press.
Lander, A Preventing alcohol-related violence: A community action manual , Darlinghurst, Australia: Eastern Sydney Area Health Service and St. Vincent's Alcohol & Drug Service.
League of California Cities conditional-use permit ordinances and alcohol-related problems survey. (1994). Unpublished study.
Lester, D. Restricting the availability of alcohol and rates of personal violence (suicide and homicide). Drug and Alcohol Dependence. 31:215-217. [pmid: 8462411].
Linney, J. A., & Wandersman, A Prevention Plus III: Assessing alcohol and other drug prevention programs at the school and community level, a four-step guide to useful program assessment (DHHS Pub. No. ADM 91-1817), Rockville, , MD: . Alcohol, Drug Abuse, and Mental Health Administration.
MacDonald, S. The impact of increased availability on wine in grocery stores on consumption: Four case histories. British Journal of Addiction. 81:381-387. [pmid: 3488754].
Macdonald, S., & Whitehead, P. C. Availability of outlets and consumption of alcoholic beverages. Journal of Drug Issues. 13(4):477-486.
MacKinnon, D. P., Scribner, R., & Taft, K. A. Development and applications of a city-level alcohol availability and alcohol problems database. Statistics in Medicine. 14(5--7):591-604. [pmid: 7792450].
McKnight, A. J. Factors influencing the effectiveness of server-intervention education. Journal on the Study of Alcohol. 52(5):389-397.
Mecca, A. M. (Ed.) Comprehensive alcohol & drug abuse prevention strategies , San Rafael, , CA: . California Health Research Foundation.
Mecca, A. M. (Ed.) Prevention action plan for alcohol-related problems, San Rafael, , CA: . California Health Research Foundation.
Molof, M. J., & Kimball, C Evaluation of the Oregon alcohol server training program: Report on interviews with customers of licensed alcohol-serving establishments in Oregon , Eugene: Integrated Research Services, Inc
Mosher, J The alcoholic beverage control system in California Paper presented at the Second Plenary Meeting of the International Study of Alcohol Control Experiences, Pacific Grove, , CA. .
Mosher, J. F. The impact of legal provisions on barroom behavior: Toward an alcohol-problems prevention policy. Alcohol. 1:205-211. [pmid: 6536286].
Mosher, J. F., & Colman, V Alcohol beverage control in a public health perspective: A handbook for action , San Francisco: Trauma Foundation, Center for Injury Prevention.
Mosher, J. F., Delewski, C., Saltz, R., & Hennessy, M Monterey-Santa Cruz responsible beverage service project: Final report, October 1989 , San Francisco: Trauma Foundation, San Francisco General Hospital.
Mulford, H. A., & Fitzgerald, J. L. Consequences of increasing off-premise wine outlets in Iowa. British Journal of Addiction. 83(11):1271-1279. [pmid: 3233402].
National Highway Traffic Safety Administration. (1997). Traffic safety facts 1996: A compilation of motor vehicle crash data from the Fatality Analysis Reporting System and the General Estimates System , Washington, DC: Author
National Institute on Alcohol Abuse and Alcoholism. (1990). Seventh special report to the U.S. Congress on alcohol and health (NIH Pub. No. ADM 90-1656), Rockville, , MD: . Author
Nebraska Liquor Control Act, Section 53-134 (1). (1994, Reissue).
Pentz, M. A., Alexander, P. S., Cormach, C. C., & Light, J Issues in the development and process of community-based alcohol and drug prevention: The Midwestern Prevention Project In N. Giesbrecht, et al. (Eds.), Research, action, and the community: Experiences in the prevention of alcohol and other drug problems (pp. 136--143), Rockville, , MD: . Office for Substance Abuse Prevention.
Preusser, D. F., & Williams, A. F. Sales of alcohol to underage purchasers in three New York counties and Washington, DC. Journal of Public Health Policy. 13(3):306-317. [pmid: 1401049].
Rabow, J., & Watts, R. K. Alcohol availability, alcoholic beverage sales, and alcohol-related problems. Journal of Studies on Alcohol. 43(7):767-801. [pmid: 7166942].
Rabow, J., & Watts, R. K. The role of alcohol availability in alcohol consumption and alcohol problems. Recent Developments in Alcoholism. 1:285-302.
Rimel, R. W., & Jane, J Characteristics of the head-injured patient In M. Rosenthal, E. Griffith, M. Bond, & J. Miller (Eds.), Rehabilitation of the head-injured adult, Philadelphia: F.A. Davis.
Roth, M. G Community organizing: Theory, principles, and practice (2nd ed., pp. 7 27), New York: . Harper & Row.
Rothman, J Three models of community organization practice In F. M. Cox & X. Ahers (Eds.), Strategies of community organization: A book of readings (3rd ed. pp. 22 27), New York: . Holt, Rinehart & Winston.
Russ, N. W., & Geller, E. S. Training bar personnel to prevent drunken driving: A field evaluation. American Journal of Public Health. 77(8):952-954. [pmid: 3605473].
Russo, A Alcohol outlets and alcohol problem costs in Los Angeles County and California: A summary , Los Angeles: Los Angeles County Department of Health Services.
Ryan, B., & Segars, L. Mini-marts and maxi-problems. Alcohol Health and Research World. 11:26-29.
Saltz, R. F. Research in environmental and community strategies for the prevention of alcohol problems. Contemporary Drug Problems. 15(1):67-81.
Scribner, R., Dwyer, J., & MacKinnon, D. The risk of assaultive violence associated with alcohol outlets and alcohol availability in Los Angeles county: An ecologic analysis. American Journal of Public Health. 85(3):335-340. [pmid: 7892915].
Scribner, R., MacKinnon, D., & Dwyer, J. H. Alcohol outlet density and motor vehicle crashes in Los Angeles county cities. Journal of Studies on Alcohol. 55(4):447-453. [pmid: 7934052].
Single, E. The interaction between policy and research in the implementation of server training. Addiction. 88(Suppl.):105S-113S. [pmid: 8453334].
Single, E., & Tocher, B. Legislating responsible alcohol service: An inside view of the new Liquor License Act of Ontario. British Journal of Addiction. 87(10):1433-1443. [pmid: 1422106].
Smart, R. G. The effect of licensing restrictions during 1914--1918 on drunkenness and liver cirrhosis deaths in Britain. British Journal of Addiction. 69:109-121.
Smith, L. G. Drinking behavior in relation to cause of death among U.S. adults. American Journal of Public Health. 84(9):1402-1406. [pmid: 8092362].
Tillitt, M. H The price of prohibition , New York: . Harcourt, Brace & Co.
Van Oers, J. A., & Garretsen, H. F. The geographic relationship between alcohol use, bars, liquor shops, and traffic injuries in Rotterdam. Journal of Studies on Alcohol. 54(6):739-744. [pmid: 8271811].
Wagenaar, A. C. A change from public to private sale of wine: Results from natural experiments in Iowa and West Virginia. Journal of Studies on Alcohol. 52:162-173. [pmid: 2016877].
Wagenaar, A. C., Finnegan, J. R., Wolfson, M., Anstine, P. S., Williams, C. L., & Perry, C. L Youth alcohol access: Where and how adolescents obtain alcoholic beverages Paper presented at the 18th Annual Epidemiology Symposium of the Kettil Bruun Society for Social and Epidemiological Research on Alcohol, Toronto, , Ontario, Canada.
Wagenaar, A. C., & Holder, H. D. A change from public to private sale of wine: Results from natural experiments in Iowa and West Virginia. Journal of Studies on Alcohol. 52:162-173. [pmid: 2016877].
Wagenaar, A. C., & Langley, J. D. Alcohol licensing system changes and alcohol consumption: Introduction of wine into New Zealand grocery stores. Addiction. 90:773-783. [pmid: 7633294].
Wagenaar, A. C., Murray, D. M., Wolfson, M., Forster, J. L., & Finnegan, J. R Communities mobilizing for change on alcohol: design of a randomized community trial , Minneapolis: University of Minnesota, School of Public Health, Division of Epidemiology
Wagenaar, A. C., & Streff, F. M. Public opinion on alcohol policies. Journal of Public Health Policy. 11(2):189-205. [pmid: 2365805].
Wallack, L. A community approach to the prevention of alcohol-related problems: The San Francisco experience. International Quarterly of Community Health Education. 5(2):85-102. [pmid: 20841132].
Wallack, L., Ratcliffe, J., & Wittman, F Changing perspective: Toward a redefinition of the prevention of alcohol-related problems In A. Mecca (Ed.), The future of alcoholism services in California (pp. 1 16), San Rafael, , CA: . California Health Research Foundation.
Watts, R. K., & Rabow, J. Alcohol availability and alcohol-related problems in 213 California cities. Alcoholism Clinical and Experimental Research. 7(1):47-58.
Wechsler, R Community organizing for the prevention of problems related to alcohol and other drugs , San Rafael, , CA: . Marin Institute for the Prevention of Alcohol and Other Drug Problems and the State of California Department of Alcohol and Drug Programs.
Williams, G. D., Stinson, F. S., Lane, J. D., Tunson, S. L., & Dufour, M. C Surveillance Report: Apparent per capita alcohol consumption: National, state, and regional trends, 1977--94 (Surveillance Report No. 39), Bethesda, , MD: . National Institute on Alcohol Abuse and Alcoholism.
Wittman, F. D Local regulation of alcohol availability in selected California communities: Introductory and summary findings Paper prepared for California State Health and Welfare AgencyDepartment of Alcohol and Drug Programs (Contract A-0138-2). , Berkeley, , CA: . Medical Research Institute of San Francisco, Prevention Research Group, Institute of Epidemiology and Behavioral Medicine.
Wittman, F. D Reducing environmental risk of alcohol problems In A.M. Mecca, (Ed.), Prevention action plan for alcohol-related problems (pp. 24 43), Tiburon, , CA: . California Health Research Foundation.
Wittman, F. D. Planning and programming server intervention initiatives for fraternities and sororities: Experiences at a large university. Journal of Primary Prevention. 9(4):247-269.
Wittman, F. D. Local information sources for planning alcohol/drug prevention programs , Berkeley: University of California, Institute for the Study of Social Change.
Wittman, F. D. Final report on the California Community Prevention Planning Demonstration Project , Berkeley: University of California, Institute for the Study of Social Change.
Wittman, F. D. Escondido case study (CLEW Associates, , Berkeley, , CA). .
Wittman, F. D., & Hudson, M Local initiatives to prevent problems related to alcohol availability: Notes from three communities , Berkeley: University of California, Community Prevention Planning Demonstration Project, Institute for the Study of Social Change.
Wittman, F. D., & Shane, P Manual for community planning to prevent problems of alcohol availability , Berkeley: Institute for the Study of Social Change.