# The Role of the Community in Problems Related to Alcohol Availability

As outlined in chapter 1, alcohol availability has a significant impact on the number and type of alcohol-related problems a community experiences. Local problems tied to alcohol availability include alcohol sales to minors, drinking in public and at work sites, crime and violence, loitering, excessive noise, drunk driving, illicit drug sales, and prostitution. Decreasing alcohol availability by making it less convenient to purchase and less accessible at public and social events can help assuage the consequences of alcohol use.

Communities can tackle these problems on a case-by-case basis, or they can follow the more effective strategy of working to prevent or at least reduce them through local policies and programs. In practical terms, this means putting certain limits on the retail distribution of alcohol, the operation of alcohol outlets, and the management of events at which alcohol is available.

This chapter looks at the powers and resources - many of them woefully underutilized - that communities have at their disposal to lessen local problems related to alcohol availability. The sections that follow focus on the role of community initiatives, beginning with the history behind the current U.S. system of alcohol controls and continuing with an examination of the responsibilities of State and local agencies that manage alcohol distribution and of what their coordinated prevention efforts can do to minimize alcohol-related problems at the local level.

## History of Alcohol Availability Management

Concern for the public's health, safety, and welfare has long been the cornerstone of local efforts to manage alcohol availability. In fact, many of the strategies considered or implemented by communities and legislatures in colonial times remain in use today.

Through the colonial period and up to around 1800, the local tavern served as a community's central meeting place and thus as the hub of its activities. Taverns were often deliberately situated to make it easy for local residents to stop in and socialize with their fellows. In any town that lacked a formal meeting house, it was usually the tavern that accommodated religious services as well as court sessions, voter meetings, and other local government activities. The tavern was also where community residents went for plays, concerts, and lodge meetings as well as news and political debates (Popham 1978).

In this context, tavern activities - including alcohol sales - were regulated through a combination of local ordinances, traditions, and conventions. Many towns restricted the number of taverns within their limits, and in some the tavern-keeper was voted into service by the local population and charged with maintaining community norms and expectations for moderation in serving practices, including the denial of service to known "drunkards." Patrons were to mind their "p's and q's" - pints and quarts consumed.

alcohol availability - methods and sources through which people obtain alcohol.

Early in the 19th century, alcohol-related problems were viewed primarily as individual failings born of moral laxity or criminal tendencies. Nevertheless, as drunkenness spawned community troubles, colonial governments responded with further restrictions on the number of taverns permitted in a given area. Other controls over drinking included pressure against alcohol imports and social standards for where and how drinking was permitted (Conroy 1991).

From the early 1800's until after the Civil War, the consumption of alcohol in the United States skyrocketed, in part because of its sinking production costs and rising availability as the Nation industrialized and pushed rapidly westward with the expansion of the railroads. Concomitant increases in drunkenness, violence, political unrest, and other alcohol-related problems spurred the Temperance movement, whose followers strove to maintain social order, preserve moral purity, and protect the booming industrial economy through abstinence. Temperance advocates lobbied town councils to eliminate or at least reduce drinking through restrictions on the number and location of taverns and roadhouses (Gusfield 1991).

After the Civil War, the United States' rapid industrialization produced many wonders, among them a radically increased capacity to produce and supply alcoholic beverages to a fast-growing Nation. Advances in bottle-capping and refrigeration methods allowed for the ever-quicker transport of alcohol products to large, dispersed markets. Meanwhile, a boom in immigration led to the growth of industrial cities populated by groups with cultures embodying varying beliefs and norms related to alcohol use.

Busy urban saloons began to take the place of sleepy rural taverns as the workingman's watering hole of choice. By the 1870's these saloons, amply supplied by powerful brewers and other alcohol producers, had become closely tied to various competing beverage companies. Located to attract the influx of industrial workers to U.S. cities, the saloon was designed to appeal to the factory worker who lived and worked in harsh conditions. In time, however, urban reforms created better living conditions, the marriage rate increased, and saloons lost their appeal and thus their place in the community. The new wave of immigrants came largely from Eastern European cultures that centered on drinking with friends at home rather than at the public saloons favored by their Western European predecessors. At the same time, workers' rising prosperity and distaste for exploitation combined to end the saloons' status as centers for political activity and social camaraderie (Powers 1991). Reformers branded saloons a menace to both family life and society in general (Powers 1991), bringing a rapid halt to such practices as paying wages in alcohol, permitting children to buy and drink alcohol, and allowing alcohol to be sold on Sundays, holidays, and election days.

From the 1880's until World War I, myriad progressive movements for social reform put the prohibition of alcohol at the top of their agendas. Organized opposition to saloons and alcohol use in general, impatience with glacier-paced "control" efforts, and the widespread belief that eliminating alcohol would solve America's social problems developed across the States into a broad and diverse coalition dedicated to a single aim: Prohibition. The movement to ban alcohol grew through the first two decades of the 20th century, leading to the unexpectedly quick passage in 1919 of the 18th Amendment to the U.S. Constitution, prohibiting the "manufacture, sale, or transportation of intoxicating liquors."

Prohibition faced little opposition at first and in fact enjoyed considerable popular support for several years; both alcohol consumption and alcohol-related health problems dropped sharply in the early 1920's. By the mid-1920's, however, alcohol consumption began creeping upward as Prohibition proved ever-harder to enforce with the growth of organized crime centered on illegal trafficking in alcoholic beverages. Before long, both the public and its elected officials became disillusioned with not only the lax enforcement of the law but the very concept of Prohibition (Lee 1963).

A movement to repeal the 18th Amendment gained broad-based support from the general public, government officials, and social scientists, who were inspired by the need to control crime and the desire to raise badly needed Federal revenues to study alternative alcohol-control systems that might replace Prohibition. Ultimately, concern over the public's growing disrespect for their government and the loss of Federal tax revenue from alcohol sales overshadowed any perceived benefits of Prohibition (Gusfield 1963), and on December 5, 1933, the 18th Amendment was repealed by the 21st Amendment to the U.S. Constitution. Prohibition - "The Noble Experiment" that lasted 13 years - arose and vanished via the same political mechanism: a broad-based national movement behind a single pressing issue.

## State ABC's: Managing Alcohol Availability Today

Prohibition's end was marked by the publication of Toward Liquor Control (Fosdick and Scott 1933), a study that outlined the development of a State-based system for managing alcohol availability. The study proposed that State-owned stores control off-sale facilities and regulate the sale of both light and heavy alcoholic beverages. On-sale outlets would be restricted to the sale of light beverages. Although not all of its recommendations were adopted, this study helped policymakers at State and local levels return to considering the "controls" discussed back in the Temperance movement days; it also led to the present-day State Alcoholic Beverage Control system.

### ABC Licensing and Enforcement Activities

State ABC's began to be established in 1933 in response to the alcohol-related problems that sprang up around Prohibition and the economic needs created by the Great Depression of the early 1930s. These ABC agencies worked quickly to establish controls aimed at eliminating crime and corruption in the alcoholic beverage industry, promptly removing the last vestiges of the lately flourishing illegal bootlegging industry and instituting regular collections of alcohol license fees and taxes the Nation's teetering economy so urgently needed.

The ABC's established licensing and enforcement operations to make sure that retail alcohol outlets complied with new State standards. The States approached alcohol licensing in one of two ways: license States issued private parties licenses to sell alcohol by retail, while control States allowed only their own ABC's to act as alcohol retailers (see Box). Both systems require reviews to ensure that proposed retail outlets conform to published State standards governing alcohol serving practices, permissible locations, hours of sale, and other relevant matters. ABC field officers conduct these licensing investigations and monitor the operations of existing outlets. The ABC field officers operate under the same circumstances and exercise the same powers as sworn local police officers, who are also authorized to enforce State ABC laws.

Today's State ABC's govern the manufacture, production, wholesale distribution, and retail sales of alcohol under uniform standards established in each State and integrated into a single control system designed to promote fair business practices throughout the alcoholic beverage industry. In addition, State ABC's maintain production standards, ensure proper alcohol tax collection, monitor the industry's business practices, and work to reduce alcohol-related criminal activity.

Control States and License States

The management of alcohol availability in the United States has evolved into a system that calls for States either to retain control over the off-sale retail availability of alcohol or to contract with private entities to issue off-sale retail alcohol licenses. The former are known as control States; the latter are license States. Over the past 60 years, control States have increasingly moved from monopoly to licensing systems, "privatizing" retail alcohol off-sales by issuing licenses for the off-sale of wine and beer while maintaining control of off-sale liquor outlets. Figure 2-1 shows the breakdown of control and license systems by State, outlet density, and per-adult alcohol consumption.

Figure 2-1. Adult Alcohol Consumption and Outlet Density Rates in Control and License States

The numbers above show alcohol consumption by individuals aged 14 years or older by State, as well as the density of on-sale, off-sale, and on/off-sale outlets combined (number per 1,000 population). Underage drinkers as young as 14 are included because studies of the relationship between alcohol consumption and related problem rates typically include adolescents (Edwards et al. 1994). The information in this figure should not be used to draw direct associations between outlet numbers and consumption rates; many factors affect the nationwide variations in outlet numbers and consumption rates shown here.

Both license and control States allow private on-sale retail alcohol outlets. Most States also permit combinations of on- and off-sale licenses at the same location. For example, some on-sale alcohol outlets are licensed for off-premise consumption, allowing their customers to buy, say, a six-pack of beer at the bar to take home. In addition, both license and control States issue private licenses for short-term special events. These short-term, specific "one-day" or "special event" on-sale licenses allow the holder to sell predetermined alcoholic beverages (beer, wine, or spirits) at a specific location (such as a neighborhood block party or a fundraising event at a museum) for a short period, usually 1 to 3 days.

Today, the distinction between license and control States in terms of their actual regulatory activity is difficult to discern (Gruenewald and Janes 1989), and the advantages of one type of administration over the other for preventing alcohol-related problems are ambiguous at best (Gruenewald, Madden, and Janes 1992). In studies conducted before the movement toward privatization, the use of restrictive retail alcohol control policies by States (Parker, Wolz, and Harford 1978) and by U.S. counties (Hooper 1983) was associated with lower rates of alcohol-related problems. In general, research findings support the notion that monopolies on retail alcohol sales, if operated with a view toward public health, have the potential to reduce alcohol consumption and its related problems (Edwards et al. 1994).

The numbers above show alcohol consumption by individuals aged 14 years or older by State, as well as the density of on-sale, off-sale, and on/off-sale outlets combined (number per 1,000 population). Underage drinkers as young as 14 are included because studies of the relationship between alcohol consumption and related problem rates typically include adolescents (Edwards et al. 1994). The information in this figure should not be used to draw direct associations between outlet numbers and consumption rates; many factors affect the nationwide variations in outlet numbers and consumption rates shown here.

### ABC Interactions With Other State Agencies and Local Jurisdictions

By law, States have both the power and the responsibility to regulate all aspects of alcohol availability, and they can preempt local efforts to regulate alcohol outlets. In practice, however, States share much of their power and responsibility with cities and counties; after all, decisions about the distribution and operation of alcohol outlets can best be made within the communities they affect, which are in a far better position than any State agency to manage the nuances of their relationships with alcohol outlets. Similarly, ABC's benefit from the cooperation of local police and planning departments in handling State licensing and enforcement activities.

environmental factors - factors that are external or are perceived to be external to an individual but that may nonetheless affect his or her behavior. At a narrow level these factors relate to an individual's family setting and relationships. At the broader level these refer to social norms and expectations as well as policies and their implementation.

More than 60 years after the repeal of Prohibition, the primary concerns of State ABC's remain regulation of commerce, collection of revenue, and control of crime and corruption associated with the alcoholic beverage industry (Morgan 1980). Public health and community welfare issues linked to alcohol availability are included in the State charters of many ABC's, but historically have received little attention, as State ABC's typically lack the authorization, staff, or funding to pursue such matters.

Developments over the past 20 years have, however, put increasing pressure on State ABC's to pay attention to public health and community well-being. First, as described in chapter 1, research findings concerning the nexus between communities' alcohol availability and alcohol-related problems suggest that the grouping and distribution of retail alcohol outlets deserve more attention. There is a clear need, for example, to improve assessments of the environmental factors associated with geographically clustered outlets and with those in high-risk locations, such as near college campuses and in areas where drugs are known to be sold.

Second, the advent of Federal block grants to the States in the late 1970s gave State and local alcohol and drug program agencies the added responsibility of defining their own prevention initiatives. Federal prevention grants were awarded directly to communities to stimulate local government agencies and private organizations to draw upon their own resources to solve alcohol-related problems. These developments, coupled with the growing body of research on the relationships between alcohol outlets and alcohol problems, boosted interest in local control (Wittman and Shane 1988). Communities made more and more requests for service to State ABC agencies, and local prevention programs began demanding stronger State and Federal policies to support community-level prevention efforts.

Third, many State ABC's are facing ever-greater workloads as a result of a continuing decline in their budgets - and thus their staffs - relative to the number of retail alcohol outlets and to growing State populations. In California, for example, the ratio of ABC field investigators to retail alcohol outlets soared from one officer per 43 retail outlets in 1955 to one officer per some 340 outlets in 1997, a total of 200 ABC officers for 68,000 retail outlets statewide (George Reece, Deputy Director, California Alcoholic Beverage Control Agency, personal communication to Friedner Wittman, September 1988). It is hardly surprising that many State ABC's are eager to work closely with local jurisdictions and to share the responsibility for licensing and enforcement.

## Community Prevention Initiatives

Community agencies and other organizations increasingly are recognizing that the nature and extent of alcohol availability is a source of risk to public health and safety at the local level. At the same time, policies for managing alcohol availability within the community are being viewed more and more as the joint responsibility of local government, public agencies, and community groups. As a result, prevention coalitions are forming in many communities to support the use of local powers to control alcohol-related risks.

State and local governments are well positioned to reinforce one another's efforts to manage local alcohol availability problems. The most promising means through which public agencies can minimize alcohol-related problems are as follows:

- Local zoning laws and land-use ordinances for retail alcohol outlets.
- Negotiated agreements with specific alcohol outlet operators.
- Prevention of access to alcohol by underage would-be drinkers.
- Property management procedures and architectural designs that encourage prevention.
- Regulations for the sale and use of alcohol in public places and at public events.

community - a group of individuals who share cultural and social experiences within a common geographic or political jurisdiction.

It is, of course, up to local public agencies and concerned groups to apply these measures to their community's alcohol availability-related problems. State ABC's and other outside sources of support can be of assistance once a course of action has been decided upon, but they can do little beforehand. The following sections address the leadership issues faced by local public agencies and community groups that wish to adopt prevention measures as city or county policies.

### Local Zoning Laws and Land-Use Ordinances

Over the past decade, local zoning laws and other land-use ordinances have gained popularity as a means of controlling the risks posed by alcohol outlets. Such ordinances protect the community by establishing land-use zones - districts or areas that can be used only in certain ways. These zones require operating conditions and facility designs that limit high-risk behaviors on or near the site in question; an established local review process weighs the merits of every zoning application. By setting such limits on permitted land uses and in some cases denying even those permits, zoning ordinances guard communities against a variety of hazards. For example, zoning ordinances separate industrial plants that use dangerous manufacturing processes from residential and other vulnerable areas such as hospitals and schools (Babcock 1966; Bassett et al. 1935; Christoffel and Teret 1993).

Modern zoning ordinances came into widespread use throughout the United States following a 1926 Supreme Court ruling that cities, counties, and other locally governed jurisdictions have the power to protect the public's "health, safety, welfare, and morals" (City of Euclid v. Ambler Realty Co. 1926). Over the past 70 years, local communities have effectively used zoning laws to protect the public health by assisting ABC's and other State agencies in carrying out their duties. It is therefore not surprising that State governments generally recognize the value of local zoning laws and protect their use. Most State ABC statutes provide ample latitude for the application of local zoning ordinances to State-licensed or -operated retail alcohol outlets. Typically, applicants for State ABC licenses are asked to obtain local zoning clearance before submitting their applications to an ABC.

conditional-use permit - a permit allowing the sale or consumption of alcohol that is granted pursuant to certain terms and conditions. Such permits may be awarded on a temporary or permanent basis.

Communities have a significant opportunity to manage the potentially troublesome aspects of retail alcohol availability by limiting alcohol outlets through the local zoning code (Wittman 1994), as follows:

- Density restrictions can limit the number of alcohol outlets by population, geographic area, or as a percentage of all retail alcohol outlets in a given commercial area. (Limits on the number of outlets according to population are more often found in State ABC statutes than in local ordinances.)
- Restrictions on hours of operation can limit the times when alcoholic beverages can be sold.
- Spacing restrictions can specify a minimum distance between alcohol outlets and schools, churches, residences, parks, playgrounds, or other community sites.
- Standards of operation and facility design can ensure that outlet premises are securely maintained and that staff are trained not to sell alcohol to underage youths, inebriates, or those likely to drive. Zoning ordinances may also require certain architectural design features to prevent theft or loitering (Clarke 1992).
- Types of alcohol outlets can be limited to certain zones or disallowed altogether. For example, bars that offer live entertainment generally are not permitted in residential areas, and some communities do not permit drive-through outlets anywhere.

These limits can be stated as "conditions" on the zoning permit issued to any individual establishment. Such limits may be imposed either as standard conditions (a list of the limits typically required for each application) or as discretionary conditions (restrictions applied on a case-by-case basis and tailored to the specific features of the proposal and the surrounding land area). Most communities use standard conditions supplemented by discretionary conditions as circumstances warrant (Wittman 1994).

Standard conditions designed to curtail alcohol-related problems by restricting activities in and around licensed on- and off-sale premises include the following:

- Authorizing police officers to enter a licensed alcohol outlet at any time to determine whether any regulations have been violated.
- Ensuring the presence of an on-duty employee over the age of 21 at all times when alcoholic beverages are sold.
- Hiring security guards to protect patrons and prevent damage to the premises.
- Preventing underage youth from entering the premises during certain hours or without an accompanying adult.
- Requiring Responsible Beverage Service (RBS) training for staff of retail alcohol establishments and short-term permit events.
- Requiring soundproofing and fencing to avoid disturbing neighbors.
- Restricting nude entertainment.
- Restricting the hours and days when alcohol is sold.

### "Active" and "Passive" Use of Local Zoning Ordinances

Communities may make active or passive use of local zoning ordinances. Active use requires that every application be reviewed to determine whether the proposed land use complies with the ordinance. This review weighs the risks and benefits to public health, safety, and community welfare associated with the proposal. This type of zoning is administered through conditional-use permits, which impose the conditions described above on the land-use permit application.

Procedures for case-by-case CUP review of local planning and zoning ordinances are generally the same throughout the United States. Applications for zoning permits are initiated by the property owner or a designee. Staff officials in local agencies then conduct reviews to determine whether the proposed land use meets zoning code requirements and whether problems might occur if the permit is granted. Once the official findings are completed, recommendations are made to the local zoning authority (usually a zoning review board). This local authority conducts a public review of the findings and decides whether to grant the use permit as requested, to grant it with some modifications, or to deny the request. This decision may be appealed to the local legislature and then to the courts (Babcock 1966; Bassett et al. 1935; Wittman 1982, 1994).

Under a passive review system, local zoning authorities are restricted to determining whether an application conforms to the published requirements of the local zoning code. If the proposed land use complies, a use permit is issued automatically, or "as of right."

Active zoning is preferable in preventive land use planning for retail alcohol outlets. Passive zoning does not offer the opportunity for careful review of the merits of each case; as a result, problems on an application may be overlooked. Moreover, once granted, a passive use permit cannot easily be modified or revoked unless appropriate conditions were imposed at the outset. Should problems arise later, the enforcement process is likely to take longer and will probably not be as effective as under an active use permit (Wittman and Shane 1988).

alcohol outlet - a business or location where alcoholic beverages are sold to the public or to a select membership.

Some U.S. cities and counties have been making active use of planning and zoning ordinances to prevent problems with retail alcohol outlets for 20 years (Wittman 1982, 1994). This is particularly true in California, where planning research on local zoning of alcohol outlets got under way in 1979. In 1987, at least 30 percent of the State's approximately 470 municipalities were using CUP ordinances for both on- and off-sale alcohol outlets (Wittman and Hilton 1987); a 1993 estimate by the League of California Cities suggests that about half the State's municipalities were then making active use of CUPs. Community prevention coalitions, local officials, and local police departments have found that CUP conditions for alcohol outlets provide a vital tool for controlling and preventing alcohol outlet-related problems (Wittman, Helmke, and Biderman 1992; Wittman and Shane 1988). Appendix F outlines an example of a CUP ordinance applied to prevention problems.

### Zoning Enforcement and Nuisance Abatement

Active zoning through CUP ordinances enhances enforcement efforts by allowing prompt intervention when alcohol outlets are violating their State ABC licenses or local land use permits. If an outlet violates both local zoning conditions and State licensing requirements, local authorities have greater leverage to bring the operator into compliance. If informal discussions with operators prove ineffective, their violation of CUP conditions offers grounds for revoking the local use permit. When it is clear that standards will be enforced, voluntary compliance with community standards and sensitivity to neighborhood concerns can be expected to increase.

Sometimes, however, a more forceful approach may be required. If initial attempts to obtain voluntary compliance fail, the State ABC and the local jurisdiction may take stronger action via inspections, citations, fines, and possibly revocation of the State ABC license or local use permit. Most alcohol outlet owners and operators agree to address problems if economic sanctions and revocation of their licenses and permits are at issue. Owners occasionally will take a "wait and see" attitude to test the community's willingness to enforce the zoning conditions, but most eventually comply or sell the establishment rather than face strong enforcement actions; only rarely are public agencies forced to proceed with license or permit revocations or fines.

Several communities are using CUPs to strengthen and enforce nuisance abatement laws. The nuisances referred to typically include littering, loitering, harassment of passers-by, public urination, open-air drug-dealing, and vice crimes such as prostitution and gambling. Some California communities now include special nuisance abatement provisions in CUP ordinances for alcohol outlets (Mosher and Works 1994; Wittman 1994). These ordinances facilitate prompt action by city officials once a formal determination has been made that an alcohol outlet is creating or abetting public nuisances. The active zoning ordinance's CUP conditions make it possible for zoning authorities to work directly with the outlet operator to eliminate nuisances by bringing the establishment into compliance with CUP conditions as an alternative to going to court. This approach often resolves the issues without resort to protracted and expensive legal proceedings. Under passive zoning, by contrast, the community would be required to file a court case in the first place to address the alleged nuisances (Kiley 1998).

### Regulation of Alcohol at Public Places and Events

Although the 21st Amendment to the U.S. Constitution gives States the power to regulate the sale of alcoholic beverages in public places and at public events, States often exert this control only through the minimal standard requirements they apply to one-day or other short-term licenses. What's more, States generally leave the regulation of drinking in public places to local jurisdictions. These State policies leave considerable room for local public agencies to interpret and implement specific policies and ordinances of their own. Such latitude gives communities the opportunity to prevent problems related to alcohol sales during casual uses of public spaces and at special events such as Fourth of July fireworks displays, Saturday-night dances, high-school graduations, and ethnic group celebrations.

problem outlet - a retail alcohol outlet that resists cooperation with State or local authorities or community groups in addressing high-risk practices or community complaints.

Substantial legal liability may rest with the local jurisdiction that owns or controls facilities used by the general public, whether or not alcohol is sold there. Therefore, unless reasonable measures are taken to prevent problems the use of alcohol on public property may cause, the local jurisdiction may be held liable in the event of an alcohol-related injury (Solomon et al. 1996). Public properties subject to such liability claims include the following:

- Common areas, such as plazas, squares, and courtyards.
- Facilities designed for public gatherings, such as fairgrounds, auditoriums, and stadiums.
- Parks, beaches, playgrounds, and natural open spaces.
- Streets, sidewalks, alleys, and transportation facilities.

Community policies and restrictions on drinking in public continue to spark local debate. Should the community prohibit all drinking in public? If public drinking is permitted, what constraints should be imposed to prevent problems? Traditionally, local governments have banned drinking in public to control nuisance inebriates. More recently, restrictions on drinking at public beaches and in automobiles, parks, and other recreational settings have been implemented as part of broader public safety policies that put community policing concepts to work against crime and violence at the neighborhood or district level (Edwards et al. 1994; Goldstein 1990).

Very few studies have been done on local ordinances that apply to drinking in public. Thus debate continues over whether to allow drinking in open public spaces such as parks, sports stadiums, concert halls, and arts centers. Some localities are finding that under certain circumstances controlled drinking in such places is easier to enforce and results in fewer problems than complete bans on drinking. However, local authorities may well prefer to ban all drinking at hard-to-control events such as long parades, large street fairs, and mass open-air events targeted at young people (Wittman 1997a).

For controlled drinking to be allowed, most communities require a special permit stipulating preventive measures such as the following:

- Advance public notification that preventive measures will be in effect.
- Controlled access through a supervised entrance into a fenced enclosure where alcohol is sold and consumed.
- Facility designs and operational procedures that deny underage individuals access to alcoholic beverages and that minimize risks to event attendees, for example by providing alcohol-free "family areas" at sports stadiums and allowing alcohol sales only in stadium concourses, not in the seats.
- Limits on advertising and promotion of alcohol availability in conjunction with the event.
- Prohibiting the public from bringing alcohol onto the premises and cutting off sales of alcoholic beverages at least an hour before the end of an event to avoid loosing inebriated drivers onto the streets.
- Special arrangements for security and enforcement of alcohol restrictions.

### Responsible Beverage Service Standards

Many communities' initial experiences with alcohol control policies have led local officials to adopt responsible beverage service standards for those who sell or serve alcoholic beverages at public events. RBS - a general term covering a range of preventive policies and practices for the sale and service of alcohol in retail establishments - is a powerful tool for reducing alcohol-related problems at the local level. Examples of RBS policies and programs are detailed in chapter 3.

One aspect of RBS programs is training servers in responsible beverage service practices. Another involves working with alcohol outlet owners and managers to establish prevention policies and practices that support the servers and minimize excessive or other problematic drinking. The principal goals of RBS training programs are to prevent patrons from becoming intoxicated, to ensure that intoxicated patrons are not served further or exposed to harm, and to prevent the sale of alcohol to minors. Some cities and counties include RBS training as a standard requirement for local planning and zoning ordinances, for short-term event permits, and for special events hosted or sponsored by community agencies (Wittman and Harding 1993).

RBS programs are becoming increasingly available at the local level. Some State ABC's and a number of private organizations now offer training in and consultation on RBS practices and policies. The California State ABC, for example, provides Licensee Education on Alcohol and Drugs training for all ABC licensees, while the State of Oregon requires RBS training for all commercial alcoholic beverage servers. Furthermore, California State-level organizations are being created to certify training and site-management services based on RBS standards (California Department of Alcoholic Beverage Control 1994a; Institute for the Study of Social Change 1995; Wittman et al. 1991). The not-for-profit California Coordinating Council on Responsible Beverage Service certifies or recertifies about 15 RBS training programs in the State each year (California Coordinating Council on Responsible Beverage Service 1995). The implementation and effectiveness of some of these RBS programs - particularly those produced by federally funded research projects - have been formally evaluated; see chapter 3 for details.

### Local Public Agencies as Models for Alcohol Prevention Policies

Community organizations may look to their local public agencies not only as sources of information but as models for alcohol availability policies at social events. Similarly, official personnel policies, such as limits on employee drinking at corporate events, can offer private organizations a model for planning and instituting their own workplace drinking policies. Many cities and counties have preventive policies concerning drinking at department-sponsored gatherings such as holiday parties, receptions, and other official functions. These policies contribute to the quality of the events and reduce the potential for unpleasant incidents that may lead to lawsuits or other problems.

Public agencies also can take the lead in securing sponsorship for prevention campaigns and programs that include local organizations and community groups. Anti-drinking-and-driving holiday initiatives, sober-graduation campaigns, and summer recreation programs all require working partnerships among public agencies, local businesses, and voluntary and other community organizations. Support and endorsements from public officials help such programs attain greater visibility, wider participation, and positive results.

Local authorities can also take steps to make sure their jurisdictions' prevention policies on alcohol availability are consistent across all public agencies, widely disseminated to the public, and correctly and fully applied. Consistent policies engender a supportive climate that can resonate throughout the broader community. Such consistency makes for more effective action on alcohol availability problems, which requires coordination among the State ABC; the district attorney's office; and the local police, land-use planning, and community development departments, among others. It takes both cooperation and coordination across a community to facilitate the granting of permits, the distribution and operation of new and transferred alcohol outlets, and the enforcement of local regulations.

high-risk setting - a location of alcohol outlets where the threat to the health, safety, or well-being of the community is exacerbated by other factors such as high crime rates or dangerous highways.

### Negotiating Agreements With Alcohol Outlet Operators

Problems involving alcohol outlets often can be resolved by direct negotiations between the outlet operator and the affected parties. State ABC agencies, local authorities, neighbors, or competitors can meet with the outlet operator outside the formal hearing process to establish conditions acceptable to all. When good will is present on all sides and there are no insurmountable complications, this approach can succeed. For example, a Los Angeles police officer whose family owned a convenience store in a city in northern San Diego County took immediate action upon hearing from the store's neighbors that it was a major source of calls for police service; the officer promptly replaced the store manager, who had allowed loitering and drinking on and near the premises, and conditions around the store improved dramatically (F. D. Wittman, personal communication, 1994).

Voluntary negotiations between an outlet operator and the establishment's neighbors can be conducted successfully without the presence of State or local officials, although it often helps to include them from the outset. In any case, if initial negotiations fail, the next step is to call in State ABC and local police and planning officials. They can convey to the operator the importance of responding cooperatively to problems as well as the possible consequences of not doing so under the State ABC license and local use permit.

A distinction should be made, however, between voluntary agreements negotiated for a single retail alcohol outlet and those reached with several outlets operating under a single owner or strong trade association, or with several independently owned and operated outlets. Negotiating voluntary agreements with several outlets is far harder than reaching an accord with just one, as independent owners have no way of guaranteeing one another's voluntary compliance or of ensuring that troublesome operators will participate in an agreement.

Efforts to reduce public health problems through voluntary agreements with alcohol outlet operators generally meet with limited success when several outlets in an area have a financial interest in conducting business practices that are detrimental to the public health. For example, convenience stores in a high-risk area may refuse to stop selling inexpensive, high-proof alcohol to public inebriates. Even when agreements are reached in such cases, they are often short-lived; as soon as one outlet stops honoring the voluntary agreement, the rest will likely abandon it as well (Institute for the Study of Social Change 1995).

### Preventing Access to Alcohol by Minors

Mounting evidence shows that there is a clear need for communities to increase their efforts to enact and enforce laws prohibiting alcohol sales to minors and to prevent minors from even trying to buy alcohol. Since 1984, every State has had a minimum drinking age of 21, and a number of studies indicate that the increased age limit has reduced the number of alcohol-related traffic crashes among the affected age groups (Wagenaar 1986). The increase in the minimum drinking age was also shown to reduce alcohol consumption among high school seniors - lower rates of drinking that appeared to persist as these youth entered their 20's (O'Malley and Wagenaar 1991).

Research also shows, however, that minors can easily obtain alcohol from friends or family members as well as through shoplifting and direct purchases from retailers (Wagenaar et al. 1992). Nevertheless, outlet operators are rarely punished for selling alcohol to minors, and State ABC offices lack the staff for adequate enforcement (Wagenaar and Wolfson 1994). Although research on minors' access to alcohol is in the early stages, studies of minors' access to tobacco products have resulted in numerous community-based efforts to prevent the sale of tobacco to minors. Such efforts have included merchant education and support for merchant compliance with the laws (Biglan et al. 1994; Keay et al. 1993; Skretny et al. 1990) - methods that have potential for preventing sales of alcohol to minors as well.

One strategy State ABC's and local police are using to prevent youth access to alcohol and tobacco is the "sting" or decoy-buy operation. In accordance with a procedure approved by the State ABC and administered by local law enforcement agencies, decoy-buys send minors to outlets to attempt to buy alcoholic beverages. Clerks who sell to minors are fined and the violation is recorded on the outlet owner's license. Repeat offenses can result in increasing sanctions, leading to revocation of the ABC license or local use permit. Periodic decoy-buy operations (three or more per year) have resulted in decreased sales of alcoholic beverages to decoy buyers (California Department of Alcoholic Beverage Control 1996).

### Prevention Through Architectural Design and Property Management

Certain architectural designs and property management procedures lend themselves to crime prevention through environmental design, which can prevent specific problems associated with retail alcohol outlets, such as crime, loitering, shoplifting, public intoxication, vehicular traffic, noise, bright lights, and other neighborhood disturbances. One study showed that several design features and operating practices in convenience stores affected their likelihood of being robbed. Such features and practices include secure cash-handling methods using in-store safes, open architectural designs that permit easy surveillance by police and store personnel, and following a policy of having at least two clerks in the store at night. In Florida, legislation requiring the adoption of such practices is credited with a 10-percent decrease in convenience store robberies over a period when violent crime elsewhere increased by 10 percent (Hunter and Jeffrey 1992). Crime prevention through environmental design techniques can be implemented by owners or operators of alcohol outlets either independently or in consultation with local officials, such as from the planning and police departments.

## State and Local Collaboration Initiatives

State ABC's and local jurisdictions can work together to prevent alcohol availability-related problems. Most contacts between State ABC's, local public agencies, and community groups occur on a case-by-case basis to discuss problems with individual outlets - such contacts have little preventive value. Recently, however, State ABC's, other State and Federal agencies, and private foundations have begun to expand their combined efforts to help local jurisdictions and prevention-oriented organizations develop effective policies and procedures for working with alcohol outlets at the local level. Although systematic studies of such State and local collaboration efforts are not available, several examples of successful partnerships are described in the sections that follow.

### State ABC's Sharing Authority With Local Jurisdictions

Several natural experiments that arose spontaneously in the course of policy development have strengthened the bonds between State ABC's and local alcohol control systems by increasing the authority or capacity of local jurisdictions to assist State ABC licensing and enforcement. Although these experiments were neither planned nor thoroughly documented, their results offer important lessons for future initiatives:

- A California State Assembly member convened a panel to draft a model zoning ordinance to strengthen local control over alcohol outlets (Model Zoning Ordinance 1987). Many California cities and counties have used this model ordinance when drafting local zoning regulations. The use of planning and zoning ordinances has strengthened the connections between communities and the ABC regarding licensing and enforcement.
- Although local jurisdictions generally have the authority to enforce State ABC laws, many local law enforcement agencies lack training in administering the laws. To rectify this situation, the California Department of Alcoholic Beverage Control now awards $100,000 development grants to local police departments to improve their alcohol licensing and enforcement activities (California Department of Alcoholic Beverage Control 1994b).
- Because decoy-buy operations have been demonstrated to have the short-term effect of suppressing sales of alcohol to minors, State ABC's and local police departments can work jointly to conduct several such operations each year. The California State ABC Department has developed a manual for statewide use that codifies decoy-buy procedures for local police and sheriff's departments.
- The 1994 Nebraska Liquor Control Act gave local governing bodies several specific powers and duties, including the authority to cancel or revoke alcohol licenses for cause or for violations of the act. (Any cancellation or revocation action is subject to appeal to the State Liquor Control Commission.) The act also empowered local governments to make nonbinding recommendations to the Commission, which has the authority to approve or deny applications to serve or sell alcoholic beverages.
- Some State ABC's, such as the California Alcoholic Beverage Control Department and the Pennsylvania Liquor Control Board, have instituted programs to educate local public agencies and school-age youth about alcohol availability-related problems and ABC operations.

### Support From Other State and Federal Agencies

Some State alcohol and drug control agencies are encouraging municipalities and other local jurisdictions to become more active in addressing community problems related to alcohol availability (Casswell et al. 1989; Greenfield and Zimmerman 1993). That said, there is wide variation in the extent to which different State agencies support local efforts to improve controls on alcohol availability. Some, like the California Department of Alcohol and Drug Programs, provide technical assistance, information dissemination, statewide conferences, and consultations on county initiatives in environmental prevention (Wittman 1992, 1997b; Wittman and Biderman 1993).

Federal demonstration grants and community trial projects have generated significant support for the development of local controls. From 1990 to 1995, the National Institute on Alcohol Abuse and Alcoholism funded projects for community prevention in several cities in California, Minnesota, and South Carolina, which were systematically evaluated (Addiction June 1997). These projects document problems related to retail alcohol availability and report on community-level strategies for addressing those problems. The U.S. Department of Health and Human Services' Center for Substance Abuse Prevention (CSAP) includes "environmental" and "community-based" approaches to alcohol and drug problem prevention among the six types of local prevention activities that it funds (Center for Substance Abuse Prevention, Federal Register March 31, 1993).

Private foundations have also played a key role in supporting community-level prevention initiatives. The Robert Wood Johnson Foundation, for instance, provides extensive support through "Fighting Back" Partnership programs (administered by Join Together, Boston University School of Public Health) in several cities. Other programs use environmental approaches to prevention and focus on the use of zoning ordinances, RBS programs, and other strategies for working directly with retail alcohol outlets. Foundations also support grassroots efforts to protest alcohol availability in high-risk inner-city and Native American communities (Aguirre-Molina 1991; Mosher and Works 1994).

### Knowledge Dissemination

State, Federal, and foundation sources all support knowledge dissemination activities such as this guide. CSAP also supports various information dissemination activities through the National Clearinghouse for Alcohol and Drug Information, the National Center for the Advancement of Prevention, and the regional Centers for the Application of Prevention Technology. These organizations offer conferences, seminars, technical assistance, and publications that include research summaries and information on best practices. The Robert Wood Johnson Foundation's Join Together program also distributes a range of pertinent materials on community-level approaches to prevention.

## Challenges to Strengthening Controls at the Local Level

The local policy tools and initiatives described in this chapter indicate the potential for communities to assume greater responsibility for alcohol outlets at the local level. In several respects, however, States have been slow to expand ABC activities specifically to address public health problems or to increase local authority for oversight of retail alcohol outlets. The sections that follow briefly describe several factors that have prevented faster strengthening of State and local connections: limited use of taxation and fees, constraints on staffing resources, and the lack of data on retail alcohol sales and their relationship to community problems.

### Limited Use of Taxation and Fees

The debate over taxation continues in every State from one decade to the next: Should alcoholic beverages be taxed at higher rates? Should taxation authority be extended to the local level? Such debates may intensify as research continues to confirm that higher prices for alcoholic beverages are associated with decreases in public health and safety problems (Edwards et al. 1994).

To date, local taxes on alcohol have rarely been imposed because States are generally reluctant to grant such authority to local governments. However, local agencies are typically allowed to charge permit-filing and business-license fees to cover the jurisdiction's full administrative and enforcement costs related to alcohol outlets. Some communities have begun charging nonrefundable permit-filing fees that range from a few hundred to a few thousand dollars and reflect the full cost of processing and enforcing applications for zoning permits (Wittman, Helmke, and Biderman 1992).

The ongoing debate at Federal and State levels over raising taxes on alcoholic beverages affects local prevention efforts in several ways. Higher excise taxes and State fees on alcohol could be used to increase staffing levels and otherwise strengthen the capacity of ABC and other State agencies to assist local communities. Higher taxes and fees would also reduce alcohol consumption and related problems (Edwards et al. 1994). Many cities and counties would probably pass legislation to increase local taxes on alcoholic beverages if permitted to do so by the State.

### Constraints on Staffing Resources

The ratios of State ABC staff to the number of retail alcohol outlets, which have declined steadily for decades, are now below the levels originally set for some ABC agencies. Some States also continue to pursue the privatization of alcohol outlets, doing relatively little to restrain their proliferation (see chapter 3). ABC's in many States face such backlogs in satisfying day-to-day licensing demands that they must confine their enforcement efforts to only the most troublesome cases.

Because the resources of State-based ABC's are limited, comparatively little staff time is spent on prevention initiatives and routine surveillance (Gruenewald, Madden, and Janes 1992). The current regulatory process tends to be case-oriented and reactive, triggered by requests from retailers seeking licenses and driven by complaints about existing outlets filed by local officials and neighbors (Wittman 1982).

data - information collected according to a methodology using specific research methods and instruments.

Operating an ABC on a case-by-case basis is time-consuming and expensive. ABC's must operate according to State law when processing license applications. Case reviews to deny a new license or to sanction an existing establishment require a considerable investment of staff time and expertise. Licenses cannot be denied unless a background investigation shows that an applicant is unfit or that neighbors or public agencies can demonstrate a well-documented threat to public health and safety. ABC's will not deny or sanction licenses simply because of community disapproval of drinking; to influence licensing decisions, protesting local agencies or community groups must demonstrate that the applicant is likely to create specific problems (e.g., that children at play might be endangered by inebriated drivers leaving a neighborhood bar). It is not uncommon for licensing and enforcement actions to take months or even years to complete.

### Lack of Community Data on Problems Related to Alcohol Outlets

State agencies do not routinely report data about community alcohol problems in relation to outlet types or geographic areas. Similarly, local police generally do not file regular reports on alcohol-law violations by outlet type or police beat. The State ABC and most local police departments do, however, provide detailed information on police complaints and other problems associated with specific alcohol outlets on an as-needed basis in individual cases. But this information is often provided after the fact, in connection with enforcement activities following numerous complaints about the outlet. Because the information is not collected consistently and in a timely fashion, it is of little value in monitoring alcohol outlet control policies or in planning long-range prevention strategies.

Likewise, the State agencies responsible for assessing and collecting taxes generally do not report alcohol sales separately by retail outlets. This makes it difficult for researchers to include consumption variables in studies of the relationships between alcohol outlets and alcohol- related problems. States could readily report information about alcohol sales volumes and dollar amounts if they chose to do so.

Researchers and information specialists have assembled much information illuminating the underlying nexus of relationships among types of alcohol outlets, geographic locations, and patterns of alcohol-related problems. Until recently, special expertise at high cost was required to manage these data, which typically are collected for a limited time and for the limited purposes of a specific research project. Findings based on this information are useful to local communities and State ABC's for general prevention planning, as described in chapter 3, but this information is not immediately useful for managing alcohol outlets at the community level. In fact, State ABC's and local agencies lack the capacity to collect and analyze such data on their own.

Recent advances in the development of geographic information systems (GIS) and computer software for their use have made it possible to describe alcohol-related problems in relation to retail alcohol outlets at the community level. State ABC's and local police departments can now routinely observe public health and safety problems related to alcohol outlets in the environmental contexts of time, location, and type of setting, including all types of on- and off-sale outlets according to State licensing nomenclature and local land use categories (Harding and Wittman 1995). Following pilot tests in several California cities, a local GIS-format Alcohol/Drug Sensitive Information Planning System has been developed to provide such information based on continuous reporting of alcohol and drug involvement in all calls to the police for service (Harding and Wittman 1995). This system provides local information, by time, location, and type of setting, about emerging "hot spots" and other problem trends associated with alcohol outlets in. It provides the information in a format useful to local planners for reducing alcohol-related problems by pinpointing the settings and circumstances where problems are most likely to occur.

## Conclusion

Many alcohol-related problems at the community level result largely from the local settings and circumstances of alcohol availability that compromise people's health and safety. Cities, counties, and other local jurisdictions have considerable powers and resources to manage these environments to prevent, eliminate, or at least reduce the problems associated with them. As the nexus between alcohol availability and related problems becomes clearer, State ABC's and local jurisdictions are beginning to put their capacities for prevention to greater use.

Many communities that once resolved alcohol availability-related problems solely on a reactive, law-enforcement basis are learning to prevent these problems through a combination of approaches, including preventive land use planning and community policing. The helpful yet limited resources of the State ABC system require each locality to take action on its own and build partnerships with other local and State agencies to effect the changes community members desire. Focused efforts to make full use of these powers and resources can go far toward reducing the human and financial costs of alcohol availability.

## References

Aguirre-Molina, M Communities take charge! A resource directory for the prevention of alcohol and other drug problems among youth , Piscataway, , NJ: . University of Medicine and Dentistry of New Jersey, Robert Wood Johnson Medical School, Department of Environmental and Community Medicine
Babcock, R. F The zoning game , Madison: University of Wisconsin Press
Bassett, E. M., Williams, F. B., Bettman, A., & Whitten, R Model laws for planning cities, counties, and states , Cambridge, , MA: . Harvard University Press.
Biglan, A., Henderson, J., Humphreys, D., Yasui, M., Whisman, R., Black, C., & James, L. Experimental evaluation of a community intervention to reduce youth access to tobacco. Unpublished manuscript.
California Coordinating Council on Responsible Beverage Service. (1995). Final Standard Committee report , Sacramento: Author
California Department of Alcoholic Beverage Control. (1994a). Bonafide alcohol seller/server training programs , Sacramento: Author
California Department of Alcoholic Beverage Control. (1994b). Grant Assistance to Local Law Enforcement Agencies Project-Grantee handbook , Sacramento: Author
California Department of Alcoholic Beverage Control. (1996). Minor decoy program guidelines , Sacramento: Author
Casswell, S., Gilmore, L., Maguire, V., & Ranson, R. Changes in public support for alcohol policies following a community-based campaign. British Journal of Addiction. 84:515-522. [pmid: 2743032].
Center for Substance Abuse Prevention, 58 Fed. Reg. 60 (1993).
Christoffel, T., & Teret, S. P Protecting the public: Legal issues in injury prevention , New York: . Oxford University Press.
City of Euclid v. Ambler Realty Co. 272 U.S. 365, 47 S. Ct. 114 (1926) 19, 44, 69, 75, 85.
Clarke, R. V. (Ed.) Situational crime prevention: Successful case studies , New York: . Harrow and Heston Publishers.
Holder, H. D., Saltz, R. F., Grube, J. W., Voas, R. B., Gruenewald, P. J., & Treno, A. J. A community prevention trial to reduce alcohol-involved trauma. Addiction. 92, (Suppl. 2).
Conroy, D. W Puritans in taverns: Law and popular culture in colonial Massachusetts, 1630--1720 In S. Barrows & R. Room (Eds.) Drinking behavior and belief in modern history , Berkeley: University of California Press.
Edwards, G., Anderson, P., Babor, T. F., Casswell, S., Ferrence, R., Giesbrecht, N., Godfrey, C., Holder, H. D., Lemmens, P., Mäkelä, K., Midanik, L. T., Norström, T., Österberg, E., Romelsjö, A., Room, R., Simpura, J., & Skog, O Alcohol policy and the public good , New York: . Oxford University Press.
Fosdick, R. B., & Scott, A. L Toward liquor control , New York: . Harper & Brothers Publishers.
Goldstein, H Problem-oriented policy , New York: . McGraw-Hill Publishing Company.
Greenfield, T., & Zimmerman, R. (Eds.) Experiences with community action projects: New research in the prevention of alcohol and other drug problems (SAMHSA/CSAP Prevention Monograph, No. 14, DHHS Pub. No. ADM 93-1976), Washington, DC: U.S. Government Printing Office
Gruenewald, P. J., & Janes, K Alcohol control in the United States: The range of regulation Alkoholipolitikka [Finland], 54(1) 29 35
Gruenewald, P. J., Madden, P., & Janes, K. Alcohol availability and the formal power of state alcohol beverage control agencies. Alcoholism Clinical and Experimental Research. 16:591-597.
Gusfield, J. R Symbolic crusade: Status politics and the American temperance movement , Urbana: University of Illinois Press.
Gusfield, J Benevolent repression: Popular culture, social structure, and the control of drinking In S. Barrows & R. Room (Eds.) Drinking behavior and belief in modern history (pp. 399 424), Berkeley, , CA: . University of California Press.
Harding, J. R., & Wittman, F. D. GIS boosts drug prevention planning. GIS World. 8(6):80-83.
Hooper, F The relationship between alcohol control policies and cirrhosis mortality in United States counties Paper presented at the annual meeting of the American Public Health Association, Dallas, , Texas..
Hunter, R. D., & Jeffrey, C. R Preventing convenience store robbery through environmental design In R. V. Clarke (Ed.), Situational crime prevention: Successful case studies (pp. 194 204), New York: . Harrow and Heston Publishers.
Institute for the Study of Social Change. (1995, October). Responsible beverage service. Community Prevention Planning Demonstration Project (Environmental Prevention Strategy Sheet, No. 105), Berkeley: University of California, Institute for the Study of Social Change
Keay, K. D., Woodruff, S. I., Wildey, M. B., & Kenney, E. M. Effects of a retailer intervention on cigarette sales to minors in San Diego County, California. Tobacco Control. 2:145-151.
Kiley, J Pressing on: Citizen action and the Oakland alcohol outlet ordinance. Case study , San Rafael, , CA: . Marin Institute for the Prevention of Alcohol and Other Drug Problems
Lee, H How dry we were: Prohibition revisited , Englewood Cliffs, , NJ: . Prentice Hall.
Model Zoning Ordinance Prepared by California Assemblyman Gary Conduit's Office (Available from University of California at Berkeley, Community Prevention Planning and Demonstration ProjectInstitute for the Study of Social Change.)
Morgan, P. The state as mediator: Alcohol problem management in the postwar period. Contemporary Drug Problems. 9(1):107-140.
Mosher, J. F., & Works, R.M Confronting Sacramento: State preemption, community control, and alcohol-outlet blight in two inner-city communities , San Rafael, , CA: . Marin Institute for the Prevention of Alcohol and Other Drug Problems
O'Malley, P., & Wagenaar, A. Effects of minimum drinking age laws on alcohol use, related behaviors, and traffic crash involvement among American youth: 1976--1987. Journal of Studies on Alcohol. 52:478-491. [pmid: 1943105].
Parker, D., Wolz, M., & Harford, T. The prevention of alcoholism: An empirical report on the effects of outlet availability. Alcoholism Clinical and Experimental Research. 2(4):339-343.
Popham, R. E The social history of the tavern In Y. Israel, F. B. Glaser, H. Kalant, R. E. Popham, W. Schmidt, & R. G. Smart (Eds.)Research advances in alcohol and drug problems (Vol. IV pp. 225 302), New York: .
Powers, M Decay from within: The inevitable doom of the American saloon In S. Barrows & R. Room (Eds.) Drinking behavior and belief in modern history (pp. 112 131), Berkeley: University of California Press
Skretny, M. T., Cummings, K. M., Sciandra, R., & Marshall, J. An intervention to reduce the sale of cigarettes to minors. New York State Journal of Medicine. 90:54-55. [pmid: 2304661].
Solomon, R. M., Usprich, S. J., Douglas, R. R., Kiss, L., & Prout, L Municipal alcohol policy: Liability, prosecution, and risk minimization , Toronto,, Ontario, . Canada: Addiction Research Foundation
Wagenaar, A. C. Preventing highway crashes by raising the legal minimum age for drinking: The Michigan experience six years later. Journal of Safety Research. 17:101-109.
Wagenaar, A. C., & Wolfson, M. Enforcement of the legal minimum drinking age in the United States. Journal of Public Health Policy. 15(1):37-53. [pmid: 8027360].
Wittman, F. D Zoning ordinances, alcohol outlets, and planning: Prospects for local control of alcohol problems , Berkeley, , CA: . Alcohol Research Group
Wittman, F. D Community planning to prevent problems related to alcohol availability: Observations on the use and effectiveness of an environmental approach Paper presented at the Research Symposium on Driving Under the Influence, Ontario, . Canada.
Wittman, F. D Development and use of conditional-use permits to prevent problems related to retail alcohol outlets: An overview , Berkeley: University of California, Institute for the Study of Social Change
Wittman, F. D The environmental approach to AOD prevention , Sacramento, , CA: . California Department of Alcohol and Drug Programs Pub. No. 97--3501
Wittman, F. D., & Biderman, F The California Community Planning Demonstration Project: Experiences in planning for prevention of alcohol problems in four municipalities In Experiences with community action projects: New research in the prevention of alcohol and other drug problems (SAMHSA/CSAP Prevention Monograph No. 14, DHHS Pub. No. ADM 93--1976 pp. 102 114), Washington, DC: U.S. Government Printing Office.
Wittman, F. D., & Harding, J. R The Hayward ASIPS Project: Design and use of a community-based information planning system to prevent alcohol and other drug problems Unpublished paper prepared forCommPre, Horizon Services, IncCLEW Associates, , Berkeley, , CA..
Wittman, F. D., Helmke, C., Biderman, F., Graudenz, D., & Footer, K Alameda County community readiness project, final report, Berkeley, , CA: . CLEW Associates
Wittman, F. D., Helmke, C., & Biderman, F CUPs, redevelopment, stings, and coordination with the ABC: Experience in preventing problems with retail alcohol outlets in seven California municipalities , Berkeley, , CA: . CLEW Associates
Wittman, F. D., & Hilton, M. E Uses of planning and zoning ordinances to regulate alcohol outlets in California cities In H. Holder (Ed.) Control issues in alcohol abuse prevention: Strategies for states and communities (pp. 337 366), Greenwich, , CT: . JAI Press.
Wittman, F. D., & Shane, P A manual for community planning to prevent problems of alcohol availability (pp. 119 126), Berkeley, , CA: . Prevention Research Center