# Resource List

This resource list suggests resources readers can turn to for information about alcohol availability-related prevention approaches. Because detailed descriptions of the program planning and content of all the research studies and practice cases cited in this guide are beyond the scope of this publication (and often are not fully described even in the published reports of the research and practice studies), CSAP thought that readers interested in implementing specific strategies might want to obtain more detailed information directly from the researchers and practitioners who did the cited work.

The first section of this appendix therefore provides the names, addresses, and affiliations of the researchers and practitioners whose work was included in the evaluation of the research and practice evidence on the six prevention approaches described in chapter 3. The second section lists the various Federal agencies and nongovernmental organizations that provide information, resources, and guidance regarding alcohol availability-related interventions and programs. Some of these organizations serve as information clearinghouses, as noted in their listings.

## Researchers and Practitioners

### Researchers

- Antonia Abbey, Ph.D.
- Department of Community Medicine
- Addiction Research Institute
- Wayne State University
- 9D-5 University Health Center
- 4201 St. Antoine Boulevard
- Detroit, MI 48201

- Thomas Babor, Ph.D., M.P.H.
- Department of Community Medicine
- University of Connecticut
- 263 Farmington Avenue
- Farmington, CT 06030-1910

- Sally Casswell, Ph.D.
- Alcohol and Public Health Research Unit
- Department of Community Health
- University of Auckland School of Medicine
- Private Bag 92019
- Auckland, New Zealand

- Douglas Coate, Ph.D.
- Professor
- Department of Economics
- Rutgers University
- 360 Martin Luther King, Jr. Boulevard
- Newark, NJ 07102

- Philip Cook, Ph.D.
- Sanford Institute of Public Policy
- Duke University
- 124 Sanford Institute Building
- Box 90239
- Durham, NC 27708-0239

- Ron Douglas, Ph.D.
- Community Programs and Services
- Addiction Research Foundation
- 33 Russell Street
- Toronto, ON, Canada P3C 1X3

- Kaye Fillmore, Ph.D.
- Institute for Health and Aging
- 3333 California Street, Room 340
- San Francisco, CA 94118
- (415) 502-0200

- J.L. Fitzgerald, Ph.D.
- Division of Alcohol Studies
- Department of Psychiatry
- University of Iowa
- Iowa City, IA 52242

- Jean L. Forster, Ph.D., M.P.H.
- Division of Epidemiology
- School of Public Health
- University of Minnesota
- 300 West Bank Office Building
- 1300 South Second Street, Suite 300
- Minneapolis, MN 55454-1015

- Scott Geller, Ph.D.
- Department of Psychology
- Virginia Polytechnic Institute and State University
- 5088 Derring Hall
- Blacksburg, VA 24061-0436

- Norman Giesbrecht, Ph.D.
- Prevention and Health Promotion Research and Development Department
- Addiction Research Foundation of Ontario
- 33 Russell Street
- Toronto, ON, Canada M5S 2S1

- Louis Gliksman, Ph.D.
- Social Evaluation and Research Department
- Addiction Research Foundation of Ontario
- The Gordon J. Mogenson Building
- 100 Collip Circle
- University of Western Ontario Research Park
- London, ON, Canada N6G 4X8

- Paul Gruenewald, Ph.D.
- Prevention Research Center
- Pacific Institute for Research and Evaluation
- 2150 Shattuck Avenue, Suite 900
- Berkeley, CA 94704

- William Hansen, Ph.D.
- Tanglewood Research, Inc.
- PO Box 1772
- Clemmons, NC 27012

- Ralph Hingson, Sc.D.
- Social and Behavioral Sciences Department
- School of Public Health
- Boston University
- 85 East Newton Street M840
- Boston, MA 02118

- Harold Holder, Ph.D.
- Director
- Pacific Institute for Research and Evaluation
- 2150 Shattuck Avenue, Suite 900
- Berkeley, CA 94704

- Paul Kohn, Ph.D.
- Department of Psychology
- Faculty of Arts
- York University
- 4700 Keele Street
- Toronto, ON, Canada M3J 1P3
- (416) 595-6017

- David Lester, Ph.D.
- Center for the Study of Suicide
- RR41, 5 Stonegate Court
- Blackwood, NJ 08012-5356

- David Levy, Ph.D.
- Economics and Finance
- University of Baltimore
- 1420 North Charles Street
- Baltimore, MD 21201

- Scott Macdonald, Ph.D.
- Addiction Research Foundation
- University of Western Ontario
- 100 Collip Circle, Suite 200
- London, ON, Canada N6G 4X8

- David P. MacKinnon, Ph.D.
- Department of Psychology
- Arizona State University
- Tempe, AZ 85287-1104

- A. James McKnight, Ph.D.
- National Public Services Research Institute
- 8201 Corporate Drive, Suite 220
- Landover, MD 20785

- Martin Molof, Ph.D.
- Integrated Research Services, Inc.
- 66 Club Road
- Eugene, OR 97401

- Linda Mooney, Ph.D.
- Associate Professor
- Department of Sociology
- East Carolina University
- Greenville, NC 27858

- James Mosher, J.D.
- Marin Institute for the Prevention of Alcohol and Other Drug Problems
- 24 Belvedere Street
- San Rafael, CA 94901

- H.A. Mulford, Ph.D.
- Professor Emeritus
- Division of Alcohol Studies
- Department of Psychiatry
- College of Medicine
- University of Iowa
- Iowa City, IA 52242

- Sturla Nordlund
- National Institute for Alcohol and Drug Research
- Dannevigsveien 10
- 0463 Oslo, Norway
- (22) 38-04-85

- Patrick O'Malley, Ph.D.
- Senior Research Scientist
- nstitute for Social Research
- University of Michigan
- 426 Thompson Street, Room 2311
- Ann Arbor, MI 48106-1248

- Mary Ann Pentz, Ph.D.
- Department of Preventive Medicine
- School of Medicine
- University of Southern California
- USC Norris Comprehensive Cancer Center
- 1441 Eastlake Avenue, MS-44
- Los Angeles, CA 90033-0800

- William Ponicki, M.A.
- Research Associate
- Prevention Research Center
- Pacific Institute for Research and Evaluation
- 2150 Shattuck Avenue, Suite 900
- Berkeley, CA 94704

- David Preusser
- Preusser Research Group
- 60 Oak Ridge Drive
- Bridgeport, CT 06611-2411

- Henry Saffer, Ph.D.
- Research Associate
- National Bureau of Economic Research
- Kean College of New Jersey
- 50 East 42nd Street, 17th Floor
- New York, NY 10017-5405

- Richard Scribner, M.D., M.P.H.
- Assistant Professor of Public Health and Preventive Medicine
- Louisiana State University Medical Center
- 1600 Canal Street, Room 800
- New Orleans, LA 70116

- Reginald D. Smart, Ph.D.
- Social and Evaluation Research Department
- Addiction Research Foundation
- 33 Russell Street
- Toronto, ON, Canada M5S 2S1

- Alexander Wagenaar, Ph.D.
- Division of Epidemiology
- School of Public Health
- University of Minnesota
- 1300 South Second Street, Suite 300
- Minneapolis, MN 55415
- (612) 624-8370

- Friedner Wittman, Ph.D.
- President
- CLEW Associates
- 2198 Sixth Street
- Berkeley, CA 94710

### Practitioners

- Donna Dossey
- Traffic Safety Bureau
- Transportation Programs Division
- New Mexico Highway and Transportation Department
- 604 West San Mateo
- Santa Fe, NM 87504-1149

- Manuel Espinosa
- California Alcohol Beverage Control
- 3810 Rosin Court, Suite 150
- Sacramento, CA 95834

- Lynne Krukosky
- Cape May County Council on Alcoholism and Drug Abuse
- Cape May Courthouse
- 6 Moore Road
- Cape May, NJ 08210

- Judy Sanders
- Community and Targeted Initiatives
- Housing and Community Development
- City of Portland, Oregon
- 808 Southwest Third Avenue, Suite 600
- Portland, OR 97204

- Steven Schmidt
- Alcohol Education Program
- Bureau of Alcohol Education
- Pennsylvania Liquor Control Board
- Northwest Office Building, Room 602
- Harrisburg, PA 17124-0001

- Nick Teare
- Techniques for Effective Alcohol Management Coalition
- 7910 Woodmont Avenue, Suite 400
- Bethesda, MD 20814

- Dee Thomas
- Prevention Director
- Responsible Beverage Service Program
- Lincoln Council on Alcoholism and Drugs, Inc.
- 914 A Street, Suite A
- Lincoln, NE 68508

## Agencies, Organizations, and Foundations

### Government Agencies

- Bureau of Alcohol, Tobacco, and Firearms
- Distilled Spirits and Tobacco Branch
- 650 Massachusetts Avenue, NW
- Washington, DC 20226
- (202) 927-8140
- Internet: http://www.atf.treas.gov

- Center for Substance Abuse Prevention
- 5600 Fishers Lane
- Rockwall II, Suite 800
- Rockville, MD 20857
- (301) 443-0373
- Internet: http://www.health.org

- Division of Community Education
- 5600 Fishers Lane
- Rockwall II, Suite 800
- Rockville, MD 20857
- (301) 443-0373
- Internet: http://www.health.org

- Division of Public Education and Dissemination
- 5600 Fishers Lane
- Rockwall II, Eighth Floor
- Rockville, MD 20857
- (301) 443-0373

- National Clearinghouse for Alcohol and Drug Information
- PO Box 2345
- Rockville, MD 20847-2345
- (800) 729-6686
- Internet: http://www.health.org

- Centers for Disease Control and Prevention
- 1600 Clifton Road, NE
- Atlanta, GA 30333
- (404) 639-3311
- (770) 488-5705 (publication requests)
- Internet: http://www.cdc.gov/tobacco

- Indian Health Service
- Alcoholism and Substance Abuse Programs
- Division of Clinical and Preventive Services
- 5600 Fishers Lane, Room 6820
- Rockville, MD 20857
- (301) 443-4297
- Internet: http://www.ihs.gov

- National Highway Traffic Safety Administration
- Traffic Safety Programs
- 400 Seventh Street, SW
- Room 5118, NTS-11
- Washington, DC 20590
- (202) 366-9835

- National Institute on Alcohol Abuse and Alcoholism Prevention Research Branch
- Willco Building, Suite 505
- 6000 Executive Boulevard
- Rockville, MD 20892
- (301) 443-1677
- Internet: http://niaaa.nih.gov

- National Institute on Drug Abuse
- Division of Epidemiology and Prevention Research
- 5600 Fishers Lane, Room 9A-53
- Rockville, MD 20857
- (301) 443-1514
- Internet: http://nida.nih.gov

- National Transportation Safety Board
- 490 L'Enfant Plaza, SW
- Washington, DC 20594
- (202) 314-6000
- Internet: http://www.ntsb.gov

- U.S. Department of Education
- Drug Planning and Outreach
- 400 Maryland Avenue, SW
- Washington, DC 20202
- (202) 260-3954

- U.S. General Accounting Office
- 441 G Street, NW
- Washington, DC 20548
- (202) 512-3000
- Internet: http://www.gao.gov

### Nongovernmental Organizations

- Addiction Research Foundation
- Division of the Centre for Addiction and Mental Health
- 33 Russell Street
- Toronto, ON, Canada M5S 2S1
- (416) 595-6000
- (416) 595-6881 fax
- Internet: http://www.arf.org

- Alcohol Research Group
- Medical Research Institute of San Francisco
- 2000 Hearst Avenue, Suite 300
- Berkeley, CA 94709-2176
- (510) 642-5208
- (510) 642-7175 fax
- Internet: http://www.arg.org

- Center for Prevention Research
- 1151 Red Mile Road, Suite 1A
- Lexington, KY 40504
- (606) 257-5588
- Internet: http://www.uky.edu/rgs/ preventionresearch

- Center for Science in the Public Interest
- Alcohol Policies Project
- 1875 Connecticut Avenue, NW, Suite 300
- Washington, DC 20009
- (202) 332-9110
- Internet: http://www.cspinet.org

- Center of Alcohol Studies
- Rutgers University
- PO Box 969
- Piscataway, NJ 08855-0969
- (908) 445-2686
- Internet: http://www.rci.rutgers.edu/~cas2

- Community Anti-Drug Coalitions of America
- 901 North Pitt, Suite 300
- Alexandria, VA 22314
- (703) 706-0560
- (703) 706-0565 fax
- Internet: http://www.cadca.org

- Community Programs Department
- Addiction Research Foundation
- 888 Regent Street, Suite 302
- Sudbury, ON, Canada P3E 6E6
- (705) 675-1181
- Internet: http://www.arf.org

- Corporation for National Service
- 1201 New York Avenue, NW
- Washington, DC 20525
- (202) 606-5000
- Internet: http://www.nationalservice.org

- Drug Abuse Prevention Research Center
- Center for the Study of Prevention Through Innovative Methodology
- Pennsylvania State University
- S. 159 Henderson Building
- University Park, PA 16802
- (814) 865-3253
- Internet: http://methcenter.psu.edu (scroll down to NIDA Center for the Study of Prevention Through Innovative Methodology)

- Higher Education Center for Alcohol and Other Drug Prevention
- 55 Chapel Street
- Newton, MA 02158-1060
- (800) 676-1730
- Internet: http://www.edc.org

- Institute for the Study of Social Change
- Community Prevention Planning Project
- University of California at Berkeley
- 2232 Sixth Street
- Berkeley, CA 94710
- (510) 540-4717

- Insurance Institute for Highway Safety
- 1005 North Glebe Road, Suite 800
- Arlington, VA 22201
- (703) 247-1500
- Internet: http://www.hwysafety.org

- Join Together
- 441 Stuart Street
- Boston, MA 02116
- (617) 437-1500
- Internet: http://www.jointogether.org

- Lindesmith Center
- 888 Seventh Avenue, Suite 2700
- New York, NY 10106
- (212) 887-0695
- Internet: http://www.lindesmith.org

- Marin Institute for the Prevention of Alcohol and Other Drug Problems
- 24 Belvedere Street
- San Rafael, CA 94901
- (415) 456-5692
- Internet: http://www.marininstitute.org

- Minority Adolescent Drug Use Prevention
- Social Psychology and Behavioral Medicine Research Group
- Department of Psychology
- University of Houston
- Houston, TX 77204-5341
- (713) 743-8555

- Multi-Ethnic Drug Abuse Prevention Research Center
- Cornell University Medical Center
- 411 East 69th Street, Room KB201
- New York, NY 10021
- (212) 746-1270
- Internet: http://www.lifeskillstraining.com

- National and Community Service Coalition
- 409 Third Street, SW
- Washington, DC 20024
- (202) 488-7378

- National Council on Alcoholism and Drug Dependence
- 12 West 21st Street
- New York, NY 10010
- (212) 206-6770
- Internet: http://www.ncadd.org

- Partnership for a Drug-Free America
- 405 Lexington Avenue
- New York, NY 10174
- (212) 922-1560
- Internet: http://www.drugfreeamerica.org

- Prevention Research Center
- 2150 Shattuck Avenue, Suite 900
- Berkeley, CA 94704
- (510) 486-1111

- Tri-Ethnic Center for Prevention Research
- Department of Psychology
- Colorado State University
- Clark Building, Room c-78
- Fort Collins, CO 80523
- (970) 491-7902

- Wisconsin Clearinghouse for Prevention Resources
- University Health Services
- University of Wisconsin at Madison
- 1552 University Avenue
- Madison, WI 53705
- (800) 322-1468
- Internet: http://www.uhs.wisc.edu/wch