# The Campaign to Rebuild South Central Los Angeles Without Liquor Stores

In the early 1980s, like many urban communities across the nation, South Central Los Angeles experienced a sharp decline in its quality of life. The nationwide economic recession, the loss of heavy industry, and Federal cutbacks in social services and job training had devastating effects on a community that already had the highest poverty rate in Los Angeles County.

The community commonly referred to as South Central Los Angeles has a population of 600,000, composed predominantly of African-Americans and Latinos. Their socioeconomic status ranges from impoverished to middle-class. The 1990 U.S. census documented the area's unemployment rate at 51 percent and its poverty rate at 30.3 percent - double that for the entire city of Los Angeles.

Approximately 22,000 manufacturing jobs in the region were permanently lost between 1980 and 1990, when heavy industries such as Firestone, Goodyear, and General Motors closed their plants (1990 census). These plants were located in South Central Los Angeles and had employed thousands of local residents. As economic conditions deteriorated, problems related to alcohol and other drug use intensified. That so many jobs permanently left the area is widely believed to be a significant factor in the number of people who took to supplementing their incomes by selling crack cocaine.

Today, an extensive underground economy in South Central Los Angeles revolves around the manufacture and distribution of illicit drugs. Drug trafficking has contributed to a critical level of gang- and non-gang-related violence. In some neighborhoods, a variety of businesses play a role in the drug industry, such as automobile towing companies, automobile dealerships, and fictitious businesses serving as fronts for the sale of cocaine. Liquor stores also play a role in the overall picture of both drug trafficking and drug use.

In many South Central Los Angeles neighborhoods, small off-sale alcohol outlets, or "corner stores," act as magnets for a variety of substance abuse problems. (A corner liquor store typically has an area of 1,200-2,000 square feet, compared with a full-service grocery store, which is defined as occupying 25,000-40,000 square feet.) Loitering, public drunkenness, public urination, gambling, prostitution, and drug dealing characterize the environment around many problem locations. Impoverished alcoholic individuals are attracted to these corner stores because panhandling or gambling on neighborhood streets to win small amounts of change makes inexpensive bottles of fortified wines (which have a high alcohol content) easily affordable. In addition, drug dealers use telephone booths outside these stores, from which they regularly obtain drug preparation and packaging supplies. Customers meet the dealers at the stores to make their transactions. In many instances, such "problem store" environments lead to violence and leave neighborhood residents exposed to potential harm when they go out to buy food or other items also available at the corner stores.

South Central Los Angeles is home to 40 percent of the city's off-sale alcohol licenses. Prior to the 1992 civil unrest sparked by the police beating of black motorist Rodney King, there were more than 700 off-sale alcohol licenses issued in South Central Los Angeles. (In comparison, the entire state of Rhode Island has issued 280 off-sale licenses covering a population of 1.3 million.) Small corner stores that primarily sell alcohol filled the gap in service left when the major grocery chains abandoned the area after the 1965 Watts riots. South Central Los Angeles now has one supermarket per 15,198 persons, as compared with the county overall, which has one store per 11,929 persons. Before the civil unrest in 1992, in one city council district with a population of 200,000, there were 250 corner liquor stores and 10 grocery stores.

In the 1960s, many of these small markets were owned by Jewish Americans. After the Watts riots, ownership of many of these stores shifted to African-Americans, and in the early and mid-1980s many shifted again, largely to ownership by Asian immigrant merchants. The ethnicity of store owners has, however, had no effect on the problems; some merchants of all ethnicities are clearly more conscientious than others and thus successful in preventing the development of a problematic environment around their stores. Where that is not the case, it is the perception of many people who live near problematic locations that the owners have little concern about how business practices such as repeated sales to loiterers and intoxicated persons and permitting couches and chairs in parking lots contribute to community problems. Some nearby residents believe that certain owners actively participate in drug trafficking, either by taking money from drug dealers to ignore their activities or by allowing or ignoring the fact that their own employees are involved in drug trafficking.

In the early 1980s, the South Central Organizing Committee (SCOC) conducted an informal needs assessment with members of their organization. SCOC is a Saul Alinsky-style coalition of churches in which participating individuals represent a member congregation. The needs assessment reported members' concerns about the growing criminal activity associated with a number of liquor stores in South Central Los Angeles. SCOC members documented panhandling, drug transactions, and examples of a variety of other criminal or nuisance activities in front of or in close proximity to many stores. SCOC organized numerous community meetings, met with public officials, protested in front of city hall, and hired attorneys to make the case for cleaning up and then regulating the stores.

The average South Central Los Angeles neighborhood comprises single-family homes, and many areas have long histories of block-level organization and involvement in activities to improve the community's quality of life. When SCOC launched its liquor store campaign, most stores were owned by African-American merchants. SCOC was successful in getting the city of Los Angeles to use a conditional-use permit process before stores were permitted to sell alcohol. This CUP process requires the city to make "findings" that the issuance of a permit would not contribute to problems and provides an avenue for community participation such as through testimony at public hearings, during which consideration is given to the anticipated effect a particular alcohol license would have on a neighborhood. Community residents can also indicate the types of measures a merchant might employ to mitigate or avoid potential problems, such as employing security guards, providing adequate lighting, and regulating hours of operation.

Although the work of the SCOC was very successful in preventing new permits for the sale of alcohol in the community, the stringent process required for new alcohol licenses did not address conditions at existing locations. Already a multi-issue organization, SCOC eventually moved on to other issues. Still, the organization's success provided the basis from which the Community Coalition for Substance Abuse Prevention and Treatment, a partnership funded by the Center for Substance Abuse Prevention, initiated its alcohol availability campaign.

In 1991, this partnership mobilized 400 volunteers to conduct a formal door-to-door needs assessment with 1,100 residents of South Central Los Angeles. The community-wide survey identified the overconcentration of liquor stores and the associated substance abuse problems as a serious concern. Residents described the problems that SCOC had documented as the same ones that had clustered around liquor stores 10 years earlier. In response to these concerns, the partnership launched a community organizing drive in August 1991 to clean up or close down problematic stores. Coalition staff and volunteer neighborhood leaders began investigating the worst offenders and working with city departments to address the problems.

The first goal of the organizing drive was to prevent the issuance of new alcohol licenses to stores that had recently opened in the area. In the course of fighting a new license, the partnership discovered that the city was proposing to eliminate citizen involvement in determining when and where alcohol could be sold. The city's proposal called for a change in the current CUP ordinance that governs the community of South Central Los Angeles. The partnership was successful in bringing this to the attention of the media and in mobilizing residents to oppose the ordinance change. At the last moment, the mayor's office agreed to abandon plans to change the ordinance and also proposed establishing a task force to examine and address the long-standing problems associated with the overconcentration of liquor stores in the area.

The first meeting of the mayor's task force took place on April 28, 1992, the night before the upheaval that occurred in the wake of the Rodney King trial. Homeowners and representatives from the mayor's office, the city's planning commission and planning department, the State ABC, and local churches met to discuss how best to expedite the existing process for revoking operating permits from nuisance locations. City officials had used their authority to close businesses that had created public nuisances in other communities, but had not used this method in South Central Los Angeles.

During the 3 days of civil unrest, more than 200 liquor stores were destroyed, including many stores SCOC leaders had identified as problematic 10 years earlier. After the violence quieted down, numerous government and nongovernmental organizations held community meetings to discuss the problems that led to the civil unrest and to identify solutions. At every meeting, the spontaneous outcry from the community was for not rebuilding the liquor stores. City officials referred residents to the partnership, resulting in hundreds of phone calls demanding that the coalition respond by preventing the rebuilding of the stores. The partnership launched its Campaign to Rebuild South Central Without Liquor Stores, and the issue became one of three or four that served as a barometer of how the rebuilding of South Central Los Angeles was taking place. The public outcry calling for alcohol outlets not to rebuild indicated bottled-up sentiments from years of unsuccessful attempts to close problem locations.

The 1992 civil unrest unleashed a strong sense of hope as well as skepticism that the disaster had caught the attention of those in power and that this time South Central Los Angeles would be rebuilt and improved. Most of the neighborhood leaders involved in the liquor store campaign, however, had lived through the civil unrest of 1965 and had seen the unfulfilled promises that followed it. They therefore believed that the liquor store campaign had to include the sort of activism and pressure tactics that worked during the national civil rights movement of the 1960s. In this spirit, the first action of the liquor store campaign was to circulate a petition, with the goal of collecting 1,000 signatures in 6 weeks. Neighborhood residents mobilized to disseminate the petition; at the end of 6 weeks 35,000 signatures had been collected.

Neighborhood churches were active in supporting the campaign and encouraged their congregations to attend public hearings. The campaign mobilized residents to attend more than 160 public hearings, to participate in numerous community marches, and to hold a number of press conferences. But the coalition did not take a rigid stand in opposition to every store's application for a rebuilding permit. Rather, the coalition and those residing within 500 feet of the stores were notified by mail when an application to rebuild was submitted. When the coalition received a written notice, staff and volunteers canvassed the neighborhood in question and assessed each case on its own merits. The coalition always supported the decisions of the residents, who in some cases were adamantly opposed to a store's rebuilding and in others willing to allow it provided the merchant made specific improvements, such as hiring a security guard and setting early closing times in residential areas. In these cases community residents provided testimony about the existence of nuisances before a store had been destroyed and made recommendations for improving the operating conditions to alleviate future problems. Operating conditions adopted during the public hearing process became legally binding on the land, such that if a location were sold, its future owners would have to maintain the same standards.

To prepare for the hearings, the Community Coalition's Street Action Team walked door to door to survey and recruit residents to testify at the public hearings. Small neighborhood meetings were held to inform residents about the hearing process and assist them in preparing testimony. In some instances, merchants from corner stores had reputations as responsible and responsive to neighborhood concerns. Local residents supported these stores and gave testimony on behalf of their owners.

Public hearings regarding rebuilding permits throughout the city were held during planning commission meetings; liquor store cases also were heard during meetings of the commission. Neighborhood residents who were active in the liquor store campaign were primarily long-term homeowners in South Central Los Angeles. When these homeowners attended the public hearings, they were often surprised at the treatment they received from the politically appointed planning commissioners - many felt they were treated with suspicion and contempt, whereas residents from more affluent sections of town were treated with respect and their concerns resulted in immediate action. In several instances, even the more affluent residents voiced their shock at the different standards of treatment.

The media's consistent attempts to characterize the liquor store issue as racially motivated presented a tremendous challenge for the partnership. Most of the destroyed stores were owned by Korean-American merchants, and the media often characterized the civil unrest as an African-American-led riot specifically targeting Korean-American merchants. The local, national, and international media that had flocked to the area in the wake of the unrest also exploited interethnic tensions in reporting the community movement to limit the rebuilding of liquor stores. By focusing their coverage on tensions between African-Americans and Korean-Americans, the media regularly rendered invisible the substantial Latino population of South Central Los Angeles. The coalition resisted the media's attempts to distort the issue by taking it out of its historical context. After all, South Central Los Angeles had a 15-year history of community activism targeting liquor stores that predated the arrival of Korean-American merchants.

In 1993, three merchants sued the city of Los Angeles to be allowed to rebuild without restrictions and asked for an injunction to halt the public hearing process. The Legal Aid Foundation represented the Community Coalition and formally intervened in the lawsuit in support of the city. Still, the coalition lacked confidence that the city would vigorously and properly defend itself and believed that the concerns of the community were distinct from the city's. In court, the city opposed the attempt at intervention, but the judge ruled in favor of the coalition, whose intervention allowed for complete access to every court document and permitted lawyers representing the coalition full participation in the court's proceedings. The merchants first sought to block the public hearing process by asking for an injunction, which was denied in the local courts. The merchants appealed this decision, but it was upheld by the California State Court of Appeals. The appellate court's decision was then upheld at the State Supreme Court level. The essence of the decision - that the city had the right to determine whether and how liquor stores were to be rebuilt - was upheld, along with the city's right to curtail and close locations associated with public nuisance problems.

The alcohol industry responded to the organizing effort by sponsoring State legislation in 1993 to preempt the power of the city to regulate the rebuilding of liquor stores destroyed in the unrest. The legislation did not pass the State Senate and was held over until the 1994 session. When the State Supreme Court decision was made public, the industry made a final attempt to pass the legislation that would have changed the State Constitution in nullifying the Supreme Court decision. The attack from the industry required that the partnership activate statewide alliances initiated in 1991. The coalition mobilized its members, and after a 2-year battle the industry's legislation was finally defeated. The decision had statewide impact, as it upheld the right of any city to regulate alcohol-related public nuisances.

Two and a half years after the upheaval, fewer than half of the stores had reopened as liquor outlets, and of those that had reopened, many had improved their business operations and had not created nuisances since. It is assumed that many landowners decided not to rebuild liquor stores and in 30 cases chose to rebuild different types of businesses, such as office buildings, restaurants, Laundromats, and apartment buildings. The Los Angeles Police Department and researchers from the University of Southern California have reported that the crime rate has declined in the neighborhoods where liquor stores previously operated.

The coalition also participated in a collaborative project with the Asian Pacific Islander Planning Committee to assist merchants in converting liquor stores to other businesses. A member of the City Council sponsored ordinances to grant incentives such as a waiver of sewage fees and a cost-free increase in square footage for businesses that elected to eliminate alcohol sales. The State legislature passed a law reducing the cost of transferring an alcohol license to another county if the transfer was out of South Central Los Angeles.

One of the primary reasons for the Community Coalition's success in the liquor store campaign was the support it received from public health activists, planners, lawyers, city bureaucrats, and elected officials across the State of California. Technical assistance was offered many times before the partnership requested such help. Occasionally, city bureaucrats discreetly offered even inside information and took the time to train partnership staff in land-use laws and how to use city ordinances. What's more, after witnessing the blatant discrimination against South Central Los Angeles homeowners who testified before the city planning commission, many predominantly white, middle-class homeowners' associations also actively supported the campaign. The San Fernando Valley Homeowners, for example, attended public hearings and provided testimony in an effort to hold the commissioners accountable for ensuring all residents received the same standard of treatment. All in all, what the coalition and its efforts proved was that communities achieve the greatest success when all their constituencies work together to solve common problems, alcohol-related and otherwise.