# State Alcoholic Beverage Control Agencies

## State-Controlled Stores System

- National Alcoholic Beverage Control Association, Inc.
- Executive Offices
- 4216 King Street
- Alexandria, VA 22302
- (703) 578-4200

## State License System

- National Conference of State Liquor Administrators
- 10 South Street, Suite 200
- Baltimore, MD 21202
- (410) 396-4380
- (410) 396-4382 fax

## Control States

### Alabama

- Alabama Alcoholic Beverage Control Board
- 2715 Gunter Park Drive West
- Montgomery, AL 36109
- (334) 271-3840
- (334) 277-2150 fax

### Idaho

- Idaho Department of Law Enforcement
- Alcohol Beverage Control Division
- 700 Stratford Lane
- PO Box 700
- Meridian, ID 83642
- (208) 884-7060

- Idaho State Liquor Dispensary
- PO Box 59
- Boise, ID 83707
- (208) 327-7301

### Maine

- Maine State Liquor Commission
- Bureau of Alcoholic Beverages & Lottery Operations
- State House, Station Number 8
- Augusta, ME 04333
- (207) 289-3721
- (207) 287-4049 fax

### Michigan

- Michigan Liquor Control Commission
- Secondary Governmental Complex
- 7150 Harris Drive
- PO Box 30005
- Lansing, MI 48909
- (517) 322-1353

### Montana

- Liquor Division
- Montana Department of Revenue
- 2517 Airport Road
- PO Box 1712
- Helena, MT 59601
- (406) 444-2460
- (406) 444-0750 fax

### New Hampshire

- New Hampshire State Liquor Commission
- Storrs Street
- PO Box 503
- Concord, NH 03301
- (603) 271-3134

### North Carolina

- North Carolina Alcoholic Beverage Control Commission
- PO Box 26687
- 3322 Garner Road
- Raleigh, NC 27611-6687
- (919) 779-0700
- (919) 662-1946 fax

### Ohio

- Ohio Department of Liquor Control
- 2323 West Fifth Avenue
- Columbus, OH 43204-3693
- (614) 644-2360

### Oregon

- Oregon Liquor Control Commission
- 9079 SE McLoughlin Boulevard
- PO Box 22297
- Portland, OR 97222
- (503) 872-5006
- (503) 652-1380 fax

### Pennsylvania

- Pennsylvania Liquor Control Board
- Northwest Office Building
- Harrisburg, PA 71724-0001
- (717)783-7637

### Utah

- State of Utah Department of Alcoholic Beverage Control
- 1625 South 900 West
- PO Box 30408
- Salt Lake City, UT 84130-0408
- (801) 973-6800
- (801) 977-6888 fax

### Vermont

- Vermont Department of Liquor Control
- Green Mountain Drive
- Drawer 20
- Montpelier, VT 05620-4501
- (802) 828-2345
- (802) 828-2803 fax

### Virginia

- Virginia Department of Alcoholic Beverage Control
- 2901 Hermitage Road
- PO Box 27491
- Richmond, VA 23261
- (804) 367-0605

### Washington

- Washington State Liquor Control Board
- Capital Plaza Building
- PO Box 43075
- Olympia, WA 98504-3076
- (206) 753-6262

### West Virginia

- West Virginia Alcohol Beverage Control Administration
- 322 70th Street SE
- Charleston, WV 25304
- (304) 558-2481
- (304) 558-0081 fax

### Wyoming

- Wyoming Liquor Commission
- 1520 East Fifth Street
- Cheyenne, WY 82002
- (307) 777-7231
- (307) 777-6255 fax

## License States

### Alaska

- Alcoholic Beverage Control Board
- 550 West Seventh Avenue
- Anchorage, AK 99501
- (907) 277-8638
- (907) 272-9412 fax

### Arizona

- Department of Liquor Licenses and Control
- 800 West Washington
- Phoenix, AZ 85007
- (602) 542-5141
- (602) 542-5707 fax

### Arkansas

- Alcoholic Beverage Control Division
- Technology Center, Suite 503
- 100 Main Street
- Little Rock, AR 72201
- (501) 682-1105

### California

- Department of Alcoholic Beverage Control
- 3810 Rosin Court, Suite 150
- Sacramento, CA 95834
- (916) 263-6900
- (916) 263-6843 fax

### Colorado

- Department of Revenue
- Liquor Enforcement Division
- 1375 Sherman Street, Room 600
- Denver, CO 80261
- (303) 866-3741
- (303) 866-4541 fax

### Connecticut

- Department of Liquor Control
- 165 Capitol Avenue
- Hartford, CT 06106
- (203) 566-5207

### Delaware

- Delaware Alcoholic Beverage Commission
- Carvel State Office Building
- 820 North French Street
- Wilmington, DE 19801
- (302) 577-3200

### District of Columbia

- Department of Consumer and Regulatory Affairs
- Alcoholic Beverage Control Division
- North Potomac Building
- 614 H Street NW, Room 807
- Washington, DC 20001
- (202) 727-7375
- (202) 727-7027 fax

### Florida

- Department of Business and Professional Regulation
- Division of Alcoholic Beverages and Tobacco
- 1940 North Monroe Street
- Tallahassee, FL 32399-1020
- (904) 488-3227
- (904) 922-5175 fax

### Georgia

- Georgia Department of Revenue
- PO Box 38368
- 270 Washington Street SW
- Atlanta, GA 30334
- (404) 656-4252
- (404) 657-6880 fax

### Hawaii

- Department of Liquor Control, County of Hawaii
- Hilo Lagoon Centre
- 101 Aupuni Street, Suite 230
- Hilo, HI 96720
- (808) 961-8218
- (808) 935-8642 fax

- Department of Liquor Control, County of Kauai
- 4280A Rice Street
- Lihue, Kauai, HI 96766
- (808) 245-6064
- (808) 245-1797 fax

- Department of Liquor Control, County of Maui
- 2145 Kauho Street, Room 107
- Wailuku, HI 96793
- (808) 243-7753
- (808) 243-7558 fax

- Liquor Commission, City and County of Honolulu
- 711 Kapiolani Boulevard, Suite 600
- Honolulu, HI 96813-5249
- (808) 527-6280
- (808) 591-2700 fax

### Illinois

- Illinois Liquor Control Commission
- 100 West Randolph Street, Suite 5-300
- Chicago, IL 60601
- (312) 814-2206
- (312) 814-2241 fax

### Indiana

- Indiana Alcoholic Beverage Commission
- 302 West Washington Street, Room E114
- Indianapolis, IN 46204
- (317) 232-2430
- (317) 233-6114 fax

### Iowa

- Alcoholic Beverage Division
- Iowa Department of Commerce
- 1918 South East Hulsizer Avenue
- Ankeny, IA 50021
- (515) 281-7400
- (515) 281-7372 fax

### Kansas

- Alcoholic Beverage Control Division
- Department of Revenue
- 4 Townsite Plaza, Suite 210
- 200 South East 6th Street
- Topeka, KS 66603-3512
- (913) 296-3946
- (913) 296-0922 fax

### Kentucky

- Department of Alcoholic Beverage Control
- 123 Walnut Street
- Frankfort, KY 40601
- (502) 573-4850
- (502) 573-5672 fax

### Louisiana

- Louisiana Department of Public Safety
- Office of Alcoholic Beverage Control
- PO Box 66404
- Baton Rouge, LA 70896
- (504) 925-4041
- (504) 925-3975 fax

### Maryland

- State of Maryland
- Comptroller of the Treasury
- Alcohol and Tobacco Tax Unit
- Louis L. Goldstein Treasury Building
- PO Box 2999
- Annapolis, MD 21404-2999
- (410) 974-3311
- (410) 974-3201 fax

- Board of Liquor License Commissioners for Baltimore City
- 10 South Street, Suite 200
- Baltimore, MD 21202
- (410) 396-4380
- (410) 396-4382 fax

### Massachusetts

- Alcoholic Beverage Control Commission
- 100 Cambridge Street, Room 2204
- Boston, MA 02202
- (617) 727-3040

### Minnesota

- Department of Public Safety
- Liquor Control Division
- 444 Cedar Street, Suite 100L
- St. Paul, MN 55101
- (612) 296-6159
- (612) 297-5259 fax

### Mississippi

- Mississippi State Tax Commission
- Alcoholic Beverage Control Division
- PO Box 540
- Madison, MS 39130-0540
- (601) 856-1301
- (601) 856-1390 fax

### Missouri

- Missouri Department of Public Safety
- Division of Liquor Control
- Harry S Truman State Office Building, Room 870
- PO Box 837
- Jefferson City, MO 65102
- (314) 751-2333
- (314) 526-4540 fax

### Nebraska

- Nebraska Liquor Control Commission
- 301 Centennial Mall South
- PO Box 95046
- Lincoln, NE 68509
- (402) 471-2571
- (402) 471-2814 fax

### Nevada

- Nevada Department of Taxation
- 1340 South Curry Street
- Capitol Complex
- Carson City, NV 89710
- (702) 687-4892

### New Jersey

- New Jersey Department of Law and Public Safety
- Division of Alcoholic Beverage Control
- 140 East Front Street
- Trenton, NJ 08625-0087
- (609) 984-2830
- (609) 633-6078 fax

### New Mexico

- Alcohol and Gaming Division
- Regulation and Licensing Department
- 725 St. Michael's Drive
- PO Box 25101
- Santa Fe, NM 87504
- (505) 827-7066

### New York

- State Liquor Authority
- 250 Broadway
- New York, NY 10007
- (212) 417-4002

### North Dakota

- Office of State Treasurer
- Alcoholic Beverage Division
- State Capitol
- Bismarck, ND 58505
- (701) 328-2643
- (701) 328-3002 fax

### Oklahoma

- Oklahoma Alcoholic Beverage Laws
- Enforcement Commission
- 4545 North Lincoln Boulevard, Suite 270
- Oklahoma City, OK 73105
- (405) 521-3484
- (405) 521-6578 fax

### Rhode Island

- Liquor Control Administration
- 233 Richmond Street
- Providence, RI 02903
- (401) 277-2562
- (401) 277-6029 fax

### South Carolina

- South Carolina Department of Revenue and Taxation
- PO Box 125
- Columbia, SC 29214-0001
- (803) 734-4440

### South Dakota

- South Dakota Department of Revenue
- 700 North Governors Drive
- Pierre, SD 57501-2291
- (605) 773-3311

### Tennessee

- Tennessee Alcoholic Beverage Commission
- 226 Capitol Boulevard, Room 300
- Nashville, TN 37243-0755
- (615) 741-1602

### Texas

- Texas Alcoholic Beverage Commission
- 5806 Mesa Drive
- Austin, TX 78731
- PO Box 13127
- Austin, TX 78711
- (512) 458-2500
- (512) 206-3350 fax

### Wisconsin

- Department of Revenue
- PO Box 8910
- Madison, WI 53708-8910
- (608) 266-2479
- (608) 264-9920 fax

- Inheritance and Excise Tax Bureau
- PO Box 8905
- Madison, WI 53708
- (608) 266-3798