# Collateral and Underresearched Areas of Interest: Suggestions and Lessons Learned

During the process of evaluating research and practice evidence for the reduction of alcohol availability, it became clear that there were several areas of prevention experience collateral to the primary topic of this guideline and that there are other areas for which there is not have sufficient research to constitute status as distinct prevention approaches or clusters. Collateral areas include "Advertising and Counteradvertising" and "Alcohol Health Warning Labels and Posters." Underresearched areas include "Facility Design Requirements," "Food Regulations and Nonalcoholic Drinks," "Loitering and Security Issues," "Restricting Beverage Quantity and Types," and "Point-of-Sale Advertisements." Some of these areas do not readily lend themselves to rigorous evaluation. Although these areas are underresearched, practical experience can contribute to lessons learned and suggestions.

## Collateral Avenues of Prevention and Alcohol Problems

### Advertising and Counteradvertising

In the 1970s and 1980s, alcohol was one of the world's most heavily advertised products. Alcohol advertising during this period associated drinking with wealth, success, prestige, and sophistication. From a public health point of view, alcohol advertising is relevant to problem prevention because it reinforces favorable attitudes toward drinking, perhaps increasing drinking among current drinkers or discouraging drinkers from cutting down or giving up (Edwards et al. 1994). Restriction on advertising is an alcohol control measure for which there is almost universal support (Medicine in the Public Interest, Inc. 1979). Most people feel it is unwise to encourage alcohol consumption through advertising, especially when it is directed at youth.

Much of the research on alcohol advertising carried out during the last two decades by public health researchers has attempted to make direct connections between the advertisements and the individual drinker. This is a difficult area in which to mount valid research; however, the scope and quality of such research in recent years has seen promising development (Edwards et al. 1994). Where it has been used, alcohol counteradvertising has often stimulated extensive public discussions and has been known to raise public consciousness. However, little is known about the long-term effects of counteradvertising.

There is a need for research on the role of local communities in alcohol advertising and promotion. Localities and State ABC's can explore the ability to use State powers to influence alcohol marketing strategies. Localities generally have the authority to regulate the amount and location of advertising and promotion, but often cannot regulate the content. Certain aesthetic factors, such as color and the use of flashing lights, can be regulated without infringing on content, making these advertisements less obtrusive to the general public. Practitioners can use the powers in their local ordinances to control the location and size of signs and other advertising. In addition, local communities should report infringements of State laws and make recommendations on restrictions on types of advertising.

Drinking establishments and other alcohol outlets commonly use advertisements in such places as building exteriors, doors and windows, interior walls, tables, and cash registers. The effect of such advertisements on the purchase and use of alcohol and on alcohol-related problems is unknown but is assumed to attract patrons, to increase intent to purchase, and to alter choices. Point-of-sale advertisement is heavily influenced by State laws and local regulations and is an area in which local communities can exert significant influence.

Studies on the effects of alcohol advertising in various media and of bans on advertising are listed in the following bibliography.

### Advertising and Counteradvertising Bibliography

Atkin, C. K. Survey and experimental research on alcohol advertising effects. In The effects of the mass media on the use and abuse of alcohol (National Institute on Alcohol Abuse and Alcoholism Monograph No. 28). Rockville, MD: NIAAA.
Atkin, C. K., & Block, M Content and effects of alcohol advertising: Report 1, Overview and summary , Springfield, , VA: . National Technical Information Service.
Atkin, C. K., Hocking, J., & Block, M. Teenage drinking: Does advertising make a difference?. Journal of Communication. 34:157-167.
Barber, J. G., Bradshaw, R., & Walsh, C. Reducing alcohol consumption through television advertising. Journal of Consulting and Clinical Psychology. 57:613-618. [pmid: 2794180].
Blane, H. T., & Hewitt, L. E. Alcohol, public education, and mass media: An overview. Alcohol, Health, and Research World. 5:2-16. [pmid: 10298028].
Breed, W. A., & Defoe, J. R. Themes in magazine alcohol advertisements. Journal of Drug Issues. 9:511-522.
Brown, R. A. Educating young people about alcohol use in New Zealand: Whose side are we on?. British Journal of Alcohol and Alcoholism. 13:199-204.
Clark, E The want makers: Lifting the lid off the world advertising industry - How they make you buy , London: Hodder and Stoughton.
Dorn, N., & South, N Message in a bottle: Theoretical overview and annotated bibliography on the mass media and alcohol , Aldershot, United Kingdom: Gower.
Edwards, G., Anderson, P., Babor, T. F., Casswell, S., Ferrence, R., Giesbrecht, N., Godfrey, C., Holder, H. D., Lemmens, P., Mäkelä, K., Midanik, L. T., Norström, T., Österberg, E., Romelsjö, A., Room, R., Simpura, J., & Skog, O Alcohol policy and the public good , New York: . Oxford University Press.
Hingson, R., McGovern, T., Heeren, T., Winter, M., & Zakocs, R Impact of the Saving Lives Program Paper presented at the 19th Annual Alcohol Epidemiology Symposium, Krakow, Poland.
Kohn, P. M., & Smart, R. G. Wine, women, suspiciousness, and advertising. Journal of Studies on Alcohol. 48:161-166. [pmid: 3560952].
Kohn, P. M., Smart, R. G., & Ogborne, A. C Effects of two kinds of alcohol advertising on subsequent consumptionJournal of Advertising, 13 34 48
Lee, B., & Tremblay, V. Advertising and the U.S. market demand for beer. Applied Economics. 24:69-76.
McCarty, D., & Ewing, J. A. Alcohol consumption while viewing alcoholic beverage advertising. International Journal of the Addictions. 18:1011-1018.
Medicine in the Public Interest, Inc. (1979). The effects of alcoholic-beverage-control laws , Washington, DC: Medicine in the Public Interest, Inc
Moskowitz, J. M. The primary prevention of alcohol problems: A critical review of the research literature. Journal of Studies on Alcohol. 50:54-88. [pmid: 2648075].
Partanen, J., & Montonen, M Alcohol and the mass media (EURO Reports and Studies 108). Regional Office for Europe, Copenhagen: World Health Organization, Regional Office for Europe
Postman, N., Nystrom, C., Strate, L., & Weingartner, C Myths, men, and beer: An analysis of beer commercials on broadcast television, 1987, Falls Church, , VA: . AAA Foundation for Traffic Safety.
Saffer, H. Alcohol advertising and alcohol abuse: Econometric evidence. In The effects of the mass media on the use and abuse of alcohol. (National Institute on Alcohol Abuse and Alcoholism Monograph No. 28). Rockville, MD: NIAAA.
Selvanathan, E Advertising and alcohol demand in the U.K.: Further resultsInternational Journal of Advertising, 8 181 188
Smart, R. G. Does alcohol advertising affect overall consumption: A review of empirical studies. Journal of Studies on Alcohol. 49:314-323. [pmid: 3050281].
Strickland, D. E Alcohol advertising: Orientations and influenceInternational Journal of Advertising, 1 307 319
Wilkinson, R The prevention of drinking problems: Alcohol control and cultural influences , New York: . Oxford University Press.
Wilks, J., Vardanega, A. T., & Callan, V. J. Effect of television advertising of alcohol on alcohol consumption and intentions to drive. Drug and Alcohol Review. 11:15-21. [pmid: 16840063].

### Alcohol Health Warning Labels and Posters

In 1988, legislation was passed requiring that alcoholic beverage containers in the United States carry a warning label. This government warning states that women should not drink alcoholic beverages during pregnancy because of the risk of birth defects and that consumption of alcoholic beverages impairs the ability to drive a car or operate machinery. A number of studies have assessed the impact of the label, possible effects of changes in its design, and the degree of public support for the label. Since that time, policy and regulatory interest in warning labels has continued to develop, and interest has been expressed in possible effects of rotating the messages, of requiring warning messages in print and broadcast advertisements, and of requiring a statement of alcohol content on all alcoholic beverage containers (Hilton 1993). Additional research will be needed to study the impact of these measures.

Some communities have laws requiring health warning posters in drinking establishments, such as warnings about drinking during pregnancy. Providing warning posters in drinking establishments can be developed in association with public health and safety campaigns, such as health department-sponsored maternal and child health educational efforts and police-sponsored drinking and driving education programs. There is anecdotal evidence suggesting that warning posters may deter some underage youth from attempting to enter alcohol establishments. Experience suggests that an alcohol health warning poster campaign is more effective in the context of a multicomponent, multimedia effort with a unified message. This can include television and radio broadcasts and print ads, as well as public service announcements, songs, videotapes, and brochures. States and communities with monopoly sales have a responsibility and a distinct opportunity to develop warning poster interventions because they have the opportunity to display the posters prominently in their stores.

Even if the effectiveness of warning labels and posters in prevention efforts cannot be adequately demonstrated, the government and the public health field have a responsibility to inform the public about the risks associated with alcohol consumption. Clearly, warning labels have a value beyond the communication of health messages and the potential changes in knowledge, beliefs, and behavior about alcohol they might bring about. Warning labels, especially when required by Federal and State governments, have the important benefit of expressing a cultural standard about drinking and alcohol-related problems.

A bibliography on warning labels and posters and their effectiveness is provided below.

### Alcohol Health Warning Labels and Posters Bibliography

Alcohol Beverage Labeling Act of 1988. U.S. Public Law 100-690, 27 USC 201-211 November 18, 1988.
Center for Science in the Public Interest. (1991). Summary of FAS warning sign and poster law, Washington, DCCenter for Science in the Public Interest
Fenaughty, A. M., & MacKinnon, D. P. Immediate effects of the Arizona alcohol warning poster. Journal of Public Policy and Marketing. 12:69-77.
Godfrey, S. S., Laughery, K. R., Young, S. L., Vaubel, K. P., Brelsford, J. W., Laughery, K. A., & Horn, E The new alcohol warning labels: How noticeable are they? Proceedings of the Human Factors Society 35th Annual Meeting pp. 446 450, San FranciscoHuman Factors Society
Graves, K. L Do warning labels on alcoholic beverages make a difference?: A comparison of the United States and Ontario, Canada between 1990 and 1991, Toronto, Ontario
Greenfield, T. K., Graves, K. L., & Kaskutas, L. A Do alcohol warning labels work? Research findings, Washington, DCNational Association for Public Health Policy
Greenfield, T. K., Graves, K. L., & Kaskutas, L. A. Alcohol warning labels for prevention: National survey findings. Alcohol, Health and Research World. 17:67-75.
Greenfield, T. K., & Kaskutas, L. A. Early impacts of alcoholic beverage warning labels: National study findings relevant to drinking and driving behavior. Safety Science. 16:689-707.
Hankin, J., Firestone, I., Sokol, R., Ager, J., & Martier, S. The alcohol beverage warning label: I. Has knowledge changed?. Alcoholism: Clinical and Experimental Research. 15.
Hankin, J., Sloan, J., Firestone, I., Ager, J., Sokol, R., & Martier, S. A time series analysis of the impact of the alcohol warning label on antenatal drinking. Alcoholism: Clinical and Experimental Research. 17:284-289.
Hilton, M. E. An overview of recent findings on alcoholic beverage warning labels. Journal of Public Policy and Marketing. 12 (1):1-9.
Kaskutas, L., & Greenfield, T Knowledge of warning labels on alcoholic beverage containers Proceedings of the Human Factors Society 35th Annual Meeting pp. 441 445, San FranciscoHuman Factors Society
Kaskutas, L., & Greenfield, T. First effects of warning labels on alcoholic beverage containers. Drug and Alcohol Dependence. 31:1-14. [pmid: 1425211].
Laughery, K. R., & Young, S. L Consumer product warnings: Design factors that influence noticeability Designing for everyone pp. 1104 1106, ParisInternational Ergonomics Association
MacKinnon, D. P., Pentz, M. A., & Stacy, A. W. The alcohol warning label and adolescents: The first year. American Journal of Public Health. 83:585-587. [pmid: 8460742].
Mayer, R. N., Smith, K. R., & Scammon, D. L. Evaluating the impact of alcohol warning labels. Advances in Consumer Research. 18:1-9.
Mazis, M. B., Morris, L. A., & Swasy, J. L. An evaluation of the alcohol warning label: Initial survey results. Journal of Public Policy and Marketing. 10:229-241.
Scammon, D. L., Mayer, R. N., & Smith, K. R. Alcohol warnings: How do you know when you've had one too many?. Journal of Public Policy and Marketing. 10:214-228.
Young, S. L Increasing the noticeability of warnings: Effects of pictorial, color, signal icon, and border Proceedings of the Human Factors Society 35th Annual Meeting pp. 580 584, San FranciscoHuman Factors Society

## Underresearched Prevention Areas Related to Alcohol Availability

### Facility Design Requirements

Requirements for the design of drinking establishments and other facilities that serve alcohol can be imposed as part of a conditional-use permit or by State or local laws. These conditions can include requirements such as providing a certain amount of space per number of customers; minimum lighting standards for both the exterior and interior of businesses; restrictions on advertising that inhibit visibility of the ads; and restrictions on quantities of sales, such as selling single cans of beer. Similarly, the building permit process within a city will include requirements and conditions that can be tailored for the prevention of alcohol-related problems, such as required seating conditions.

Laws exist that restrict or prohibit the selling of alcohol in establishments that provide adult entertainment. Certain characteristics of drinking establishments and alcohol outlets, such as number of personnel, vary greatly among outlets. Restrictions and regulations concerning facility design should be examined for their potential value in prevention efforts. Experience suggests that in spacious and cavernous clubs, especially those that allow underage youth to enter but not to drink alcohol, supervision and monitoring of underage drinking and alcohol-related problems is difficult.

Experience suggests that for convenience stores, having a single alcohol outlet operator makes it difficult to provide adequate surveillance and to check customer identification. Research should be conducted to determine whether convenience stores that have two or more clerks, along with surveillance equipment and other design features, would have reduced alcohol sales to underage youth and to intoxicated adults. There is a need for future research and demonstration projects regarding such facility design requirements.

A bibliography on facility design is provided below.

### Facility Design Requirements Bibliography

Hunter, R. D., & Jeffrey, C. R Preventing convenience store robbery through environmental design Situational crime prevention: Successful case studies pp. 194 204, New York.
Mosher, J. F. The impact of legal provisions on barroom behavior: Toward an alcohol problems prevention policy. Alcohol. 1:205-211. [pmid: 6536286].
Schaefer, J. M The physical setting: Behavior and policy Public drinking and public policy, TorontoAddiction Research Foundation
Wittman, F. D The environmental debate Alcohol: The Prevention Debate pp. 134 140, London
Wittman, F. D Reducing environmental risk of alcohol problems Prevention action plan for alcohol-related problems pp. 24 43California Health Research Foundation
Wittman, F. D Community design to prevent problems of alcohol availability: Concepts and prospects, Berkeley, CA. CLEW Associates
Wittman, F. D Community planning to prevent problems related to alcohol availability: Observations on the use and effectiveness of an environmental approachAutomobile Club of Southern California, Ontario, California. , Berkeley, CA. Institute for the Study of Social ChangeUniversity of California at Berkeley

### Food and Nonalcoholic Drinks Regulations

Research and experience suggest that consuming food and nonalcoholic beverages in drinking establishments has physiological, practical, and social components that decrease the likelihood of acute intoxication. This is in part because food consumption slows the metabolizing of alcohol. Also, consumption of food and nonalcoholic drinks takes time that might otherwise be spent drinking alcohol. In addition, consuming food and nonalcoholic drinks can promote social interactions that can slow down the rate of heavy drinking.

Regulations and policies can be established that require establishments to provide food and/or nonalcoholic drinks as well as alcoholic drinks. In some localities, all drinking establishments must serve food, with a specific ratio of food sales to alcohol sales being required. In other areas, drinking establishments provide server training for their employees to promote serving food and nonalcoholic drinks.

The promotion of food and nonalcoholic beverages in drinking establishments can be an effective tool to diminish the rate of heavy drinking and to decrease the likelihood of intoxication, and the effectiveness of this approach is heightened when it is part of a comprehensive program. Drinking establishments may have an incentive to provide food and nonalcoholic drinks to patrons because it can be profitable. However, providing food and nonalcoholic drinks might also reduce profits.

Some of the research that has been done in this area is in the context of studying Responsible Beverage Service (RBS) programs. A review of current studies on RBS effectiveness is presented in chapter 3 of this guideline. There is a need for further research on the effects of providing food and nonalcoholic drinks in mitigating intoxication-related problems, such as driving under the influence of alcohol.

### Food and Nonalcoholic Drinks Regulations Bibliography

Mosher, J. F., Delewski, C., Saltz, R., & Hennessey, M Monterey-Santa Cruz Responsible Beverage Service Project: Final report, San Rafael, CA. Marin Institute for the Prevention of Alcohol and Other Drug Problems
Russ, N. W., & Geller, E. S. Training bar personnel to prevent drunken driving: A field evaluation. American Journal of Public Health. 77:952-954. [pmid: 3605473].

### Loitering and Security Issues

Alcohol outlets and drinking establishments are often sites for problem behaviors such as loitering, drug dealing, violence, gambling, prostitution, and civil disruption. These problems occur both within and near the establishments. As a result, problems associated with alcohol outlets relate to issues of prevailing morals as well as to public health standards.

Because alcohol and other drugs often contribute to social situations that can become dangerous or even criminal, interventions can be labor-intensive, temporary, and expensive. Thus, a more effective focus is on efforts to prevent, rather than intervene in, alcohol-related problems. To prevent alcohol-related problems such as violence and loitering, many communities have focused on controlling alcohol outlet density.

Drinking establishments sometimes hire bouncers and security officers (sometimes off-duty police officers) to provide services such as age verification, paraprofessional intoxication screening, control of patrons, and prevention of driving while intoxicated. There is, however, no research on the effectiveness of bouncers and security officers on these activities. Unfortunately, bouncers and security officers introduce liability issues because patrons may be injured or may claim injury. In addition, many police departments are reluctant to allow their officers to engage in off-duty activities as security guards.

### Restricting Beverage Quantity and Types

fortified wine - a wine that has had additional alcohol, usually in the form of grape brandy, added to it either during or after fermentation.

Experience suggests that a "substitution" phenomenon occurs when restrictions are imposed on beverage quantity and types. For example, when they are deprived of alcohol in one format, drinkers will often substitute it with alcohol in another format. Experience suggests, for example, that the elimination of fortified wines leads to substitution of another alcoholic beverage. However, further research should be conducted to determine whether this is generally the case. Experience suggests that banning fortified wines leads to a reduction in criminal behavior, but research should examine this question. Prevention efforts related to fortified wines should be conducted in concert with other efforts, such as enforcement of loitering laws.

Communities have been successful in shifting the focus of community events away from alcohol use. For example, communities have been able to change the focus of county fairs and festivals from alcohol-intensive to family-centered events. For example, the Gilroy Garlic Festival in Gilroy, California, hired a public relations agency to make the focus more family-centered. Similarly, communities have been successful in developing alcohol-free alternative events during times when alcohol-intensive events are common. For instance, many communities now have "First Night" celebrations, which are large, alcohol-free festivities celebrating New Year's Eve.

### Restricting Beverage Quantity and Types Bibliography

Giesbrecht, N., & MacDonald, S. A ban of fortified wine in Northwestern Ontario and its impact on the consumption level and drinking pattern. British Journal of Addiction. 76:281-288. [pmid: 6944094].
Hoadley, J. F., Fuchs, B. C., & Holder, H. D. The effect of alcohol beverage restrictions on consumption: A 25-year longitudinal analysis. American Journal of Drug and Alcohol Abuse. 10:375-401.
Kerbs, J Fortified wine availability project report, Oakland, CA. Alameda County Department of Alcohol and Drug Programs
Mäkelä, K Types of alcohol restrictions, types of drinkers and types of alcohol damages: The case of the personnel strike in the stores of the Finnish Alcohol Monopoly Report No. 77, HelsinkiSocial Research Institute for Alcohol Studies
Mäkelä, K. Differential effects of restricting the supply of alcohol: Studies of a strike in Finnish liquor stores. Journal of Drug Issues. 10:131-144.
Medicine in the Public Interest, Inc. (1979). The effects of alcoholic-beverage-control laws, Washington. DCMedicine in the Public Interest, Inc.
Mosher, J. F. The impact of legal provisions on barroom behavior: Toward and alcohol problems prevention policy. Alcohol. 1:205-211. [pmid: 6536286].
Mulford, H. A., & Fitzgerald, J. L. The consequences of increasing off-premise wine outlets in Iowa. British Journal of Addiction. 83:1271-1279. [pmid: 3233402].
Wilkinson, R The prevention of drinking problems: Alcohol control and cultural influences, New York.