# Methodology for Arriving at Recommendations

## Analysis of Research and Practice Evidence

The analysis of research and practice evidence was conducted on two levels. First, each research study and practice case was analyzed on an individual level with regard to its design strengths, weaknesses, and potential biases. Second, each group of research articles and practice cases was analyzed with each approach.

### Individual-Level Analysis

Each research study and practice case was analyzed with regard to overall summary information, intervention factors, and research design; practice evidence was also analyzed in terms of process evaluation. The format for analyzing the research studies and practice cases - the Annotation Key - is shown in exhibit B-1.

Overall summary information included an overview or abstract of the evidence, the stated or assumed hypothesis guiding the intervention, and a description of its conceptual framework, if any. The summary included the purpose or overall rationale for the study and the objectives of the intervention. The findings were described, including primary and secondary study outcomes and unintended outcomes, if any.

A substantial amount of information was collected on each intervention. Information collected included the type of intervention; the drugs of abuse, related behaviors, and individual and environmental risk factors being studied; the target population of the intervention; the social or institutional systems involved; and the specific approaches and activities of the intervention.

The evaluation of the research designs was comprehensive and included noting the specific design employed, the specific behaviors or changes being measured, and the statistical analyses used. The process included a comprehensive review of potential biases that could have influenced the outcomes and attributions of effect.

Each prevention practice case received a process evaluation that assessed the adequacy of the quantitative and qualitative information collected.

### Group-Level Analysis (Overall Level of Evidence)

Once the research and practice evidence was analyzed at the individual level, the studies were grouped according to prevention approach and then analyzed as a group. The goal of this analysis was to determine what conclusions could be drawn about the evidence within a specific prevention approach and to ascertain the strength of the evidence supporting those conclusions. The strength or level of evidence was categorized as strong, medium, suggestive but insufficient, or substantial evidence of ineffectiveness.

### Criteria for Grading Levels of Evidence

The criterion for a strong level of evidence was consistent results of strong or medium effects from a series of studies, including at least three well-executed studies with experimental or quasi-experimental designs or two well-executed studies with experimental or quasi-experimental designs and consistent results from at least three case studies. Either way, the studies had to use at least two different methodologies, unambiguous time-ordering of the intervention and results, and a plausible conceptual model ruling out or controlling for alternative causal paths or explanations.

The criterion for a medium level of evidence was consistent positive results from a series of studies, including at least two well-executed studies with experimental or quasi-experimental designs or at least one well-executed study and three prevention case studies showing statistically significant or qualitatively clear effects. Either way, the studies had to use at least two different methodologies, unambiguous time-ordering of intervention and results when so measured, and a plausible conceptual model, whether or not competing explanations had been ruled out.

The third category, suggestive but insufficient evidence, was used to describe research and practice evidence based on a plausible conceptual model or on previous research and demonstrated in rigorous evaluation studies or appropriate intervention programs currently in progress. One of two conditions typically prompted this categorization. In the first condition, the evidence, although limited, appeared to support a conclusion, but additional research was needed to fully support that conclusion. This condition often applies to areas in which there has been little study, such as those that are impractical to research or that are new areas of study. The second condition involved equivocal results. In this condition, a specific conclusion was supported in some studies but not in others.

The three categories described above provide a way to arrange research and practice evidence for which there are varying degrees of confirmation of positive effect. A fourth category, substantial evidence of ineffectiveness, describes research and practice evidence demonstrating that a prevention approach is not effective. The criterion for inclusion in this category is the absence of a statistically significant positive or negative effect in a majority of well-executed studies, including at least two quantitative studies with sample sizes sufficient to test for the significance of the effect.

Exhibit B-1: Annotation Key
Section 1: Summary Overview Hypothesis Conceptual Framework Purpose Objectives Findings Conclusions Section 2: The Intervention Type of Intervention Drugs of Abuse Substance Abuse-Related Behaviors General Risk Factors Target Environment or Population Social or Institutional Systems Involved Strategies Activities | Section 3: Process Evaluation Number of Persons or Agencies Served Sociodemographic Information Amount of Service Provided Number of Materials Distributed and Calls Received List of Collaborators Work Plans and Progress Reports Needs Assessment Target Group Representation in Program Facilitation of Objectives by Activities Appropriateness of Materials Recipient Participation as Expected Section 4: Research Design Evaluation or Study Design Measurement Analysis Assessment of Evidence Author Discussion of Bias Comments

## Rules of Evidence Abstract

In 1992 the Center for Substance Abuse Prevention created the Prevention Enhancement Protocols System as a part of its initiatives to support and strengthen prevention systems in the United States and its territories. PEPS aims to compile, analyze, and synthesize existing knowledge on specific topics relevant to the prevention of alcohol, tobacco, and other drug problems. These problems were chosen because they represent problems considered by the field to have major consequences and because there is substantial information on these problems available to synthesize into the form of specific guidelines. The resulting PEPS guidelines are designed to assist States, practitioners, and community-based organizations with program planning and resource allocation and with choosing program options that are appropriate for the needs of their target populations.

Several previous attempts have been made by CSAP as well as other Federal, State, and community-based organizations to provide guidance to the field. PEPS, however, is the first known systematic guideline-development process in the field of substance abuse problem prevention. Although the accumulated knowledge and practice in the field of prevention in general and in substance abuse problem prevention in particular present special challenges for developing systematic guidelines, PEPS has benefited from earlier efforts by Federal agencies and professional medical societies in developing guidelines for medical practice.

Early in the PEPS program, CSAP was faced with the choice of developing guidelines through primary reliance on professional consensus or on explicit evidence. Under the former methodology, a group of well-known consultants is assembled and asked to develop guidelines based on their knowledge of the literature and their own experience. Under the latter methodology, published and unpublished evidence on a given guideline topic is researched according to a defined protocol and analyzed for validity. The accumulated evidence is then synthesized and its strength assessed according to clearly laid-out rules for the synthesis and development of recommendations based on it.

Although the evidence-based approach demanded a greater effort and investment of resources, CSAP decided that developing the guidelines on the basis of explicit evidence would provide more valid tools for prevention planners and practitioners and would also further the quest for new knowledge in areas where evidence is not strong or is lacking. To this end, the PEPS Planning Manual was developed to instruct participants in the various stages of the development of guidelines under the PEPS program.

The planning manual contains the rules of evidence document, which provides criteria for assessing the strength of available evidence for the effectiveness of substance abuse problem prevention interventions, measures, and programs. The application of the presented criteria is used by PEPS as the basis for decisions about the level of evidence available about a particular intervention. The level of evidence indicates the level of confidence that there is a causal relationship between a prevention intervention and a change in the outcomes of interest, and it indicates the overall effectiveness of the prevention activity.

The planning manual also presents definitions of research and practice evidence. These definitions are followed by summaries of methodological and design issues to be considered in assessing individual studies and programs; criteria for determining the strength of evidence for the effectiveness of an intervention, combining research and practice evidence; and procedures for specifying the conditions under which the relationship operates between a particular intervention and outcomes. The strength or level of evidence for an intervention and the conditions under which this level operates serve as recommendations to the field regarding the intervention.

The assessment criteria and levels of evidence discussed in this appendix have been developed for use in the evaluation of existing research and practice evidence. These criteria are not intended for use in designing interventions or research studies or for developing policy.

## Assessment of the Evidence

### Biases

Biases are sources of systematic errors that arise from faulty designs, poor data collection procedures, or inadequate analyses. These errors diminish the likelihood that observed outcomes are attributable to the intervention. Biases are inherently present in many nonexperimental observational studies but are of special significance in case-control studies. Experimental and quasi-experimental study designs control for many of these biases.

#### Attrition

Attrition that is nonrandom or excessive (defined as a dropout rate of 10 percent or more) in the intervention or the control group can introduce a bias in the outcome data. A differential dropout rate between the groups may also introduce a bias in outcome data.

#### Confounding Bias

An observed effect between intervention A and outcome B may be attributable to a third factor, C, which is related to both A and B. In other words, whereas the relationship between A and B may be weak or nonexistent, the explanatory relationship is between C and B. Thus, an effect can be detected that is attributable to a confounding factor rather than to the intervention or policy. Age, ethnicity, sex, and socioeconomic status are important confounders. Ways to control for confounding bias include matching techniques in the design stage and using stratification and multivariate analysis during the analysis stage.

#### Measurement Bias

Measurement bias may result when the collected information on either the exposure variable or the health state is unreliable or invalid. Historical data obtained by interviewing subjects without appropriate validation against recorded data or interviews with collateral sources are especially susceptible to what is called "recall bias." Another common type of measurement bias is the use of scales that have not been tested for reliability or validity. Ways to control for such an information bias include using only accurately recorded data, validating interview information, blinding the investigator to the identity of the case or the controls, and adhering to an explicit and standardized method of data collection.

#### Selection Bias

A selection bias results when certain individuals, knowingly or unknowingly, are selectively included or excluded from the case or the control group. The systematic and disproportionate frequency of important variables in the cases or the controls may result in a spurious measure of association. Epidemiological studies are laden with problems of selection bias. Potential problems include selective admission, selective nonparticipation, selective survival, and selective detection. An example of selection bias is a comparison group that is not equivalent to the intervention group because of demographic, psychosocial, or behavioral characteristics. Case-control studies are especially susceptible to selection bias. Thus, multiple control groups should be chosen, and at least one of the groups should come from the same source as the case group.

### Internal Validity

Internal validity is the extent to which an observed effect can be attributed to an intervention. Threats to internal validity are particularly germane to intervention studies, although policy and nonintervention studies may be susceptible to threats of statistical power, history, and unit of assignment. The overall issue regarding internal validity is whether the intervention or some other factor produced the observed effect.

#### Equivalence

For studies that have an intervention and a control or comparison group, comparisons between the two groups are most valid when they consist of subjects that are essentially similar at the beginning of the study. When this is not true, outcomes observed may not be attributable to the intervention because the groups were already different in some way.

#### Fidelity

The intervention should be delivered consistently during the intervention period. Ideally, the researchers will have used a written protocol for the intervention delivery and will have documented standard delivery to all study participants.

#### History

Significant and unplanned national, State, local, or internal organizational events or exposure occurring at the program site during the evaluation study period can result in a change among participants. In studies with a time-series design, history is the principal threat to internal validity. For these designs, it is particularly important to assess the plausibility of effects from factors such as weather, seasonality, shifts in personnel, changes in resources, or the enactment of a new law or policy.

#### Intervention Contamination

It is important for the control or comparison groups to remain unaffected by the intervention. When they are affected, the control or comparison groups may change in ways similar to the intervention group, thereby obscuring the effects of the intervention. For example, intervention contamination can result if the control or comparison group receives any information about the intervention that would affect the outcome.

#### Program or Participant Maturation

Natural, biological, social, behavioral, or administrative changes that occurred among the participants or staff members during the study period may result in program or participant maturation and could partially account for the results obtained. Such changes can include the subjects' growing older and becoming more skilled or staff becoming more effective and efficient in program delivery.

#### Randomization or Blinding of Observers

When research study staff know the status of an individual or a group (intervention or control status), they may change their own behavior in ways that can affect study outcomes. In order to minimize this bias, observers can be either blinded to the conditions or randomized to measure either intervention or comparison groups.

#### Statistical Power

There should be an adequate number of participants in each of the intervention and control or comparison groups for statistically significant differences in outcomes to be detected. A rough guide for the minimum number of participants in each group is 30. Fewer than 30 participants per group generally does not yield adequate statistical power. Regardless of the total number in a group, the groups should be about the same in size.

#### Statistical Regression

Statistical regression can result when an intervention or comparison group is selected on the basis of an unusually high or low level of a characteristic that may change naturally in subsequent measurements. The extent to which regression compromises results can be determined by examining the comparability of people who participate and those who do not. Studies employing a one-group pre-test and post-test design or a nonequivalent control group are poor at controlling for statistical regression.

#### Testing or Observation

Participants' behavior regarding study outcomes can change when they are frequently tested or observed. Measurements that occur at close points in time can also change the behavior and responses of study participants. For example, the behavior of study subjects can change because they were taking a test or were being interviewed or observed.

#### Unit of Analysis and Assignment

Participants in a prevention program can be assigned to a control or intervention condition on an individual basis or on a collective basis, such as by classroom or community. Similarly, the analysis of a research study can be done on an individual or a collective basis. The unit of assignment and the unit of analysis should be the same when researchers analyze the effects of the intervention.

#### Interactive Effects

Any combination of the preceding factors constitutes interactive effects.

### External Validity

The focus of external validity is generalizability - that is, the extent to which an observed effect that is attributable to an intervention can be expected in other settings and populations with similar or different characteristics.

#### Contextual Factors

In the substance abuse prevention field, contextual factors relate to the degree to which a community is ready to prevent substance abuse. Indicators of community readiness include favorable attitudes, norms, and restrictive policies. Studies of communities with a high degree of readiness for prevention may not be generalizable to all communities. For example, the ability to establish outdoor tobacco advertising restrictions would differ between California and North Carolina.

#### Generalizability

Factors unique to a study make it difficult to generalize the findings to similar or general populations. For instance, a school-based intervention in a primarily urban setting for African-American students may not be generalizable to a suburban school setting with primarily white students.

## References

Campbell, D., and Stanley, J Experimental and quasi-experimental designs for research , Chicago: Rand McNally.
Depression Guideline Panel. (1993). Depression in primary care, vol. 1: Diagnosis and detection Clinical Practice Guideline No. 5. AHCPR Publication No. 93-0550, Rockville, , MD: . U.S. Department of Health and Human Services.
Green, L. W., & Kreuter, M. W Health promotion planning: An educational and environmental approach , Mountain View, , CA: . Mayfield Publishing Company.
Hayward, R. S., Steinberg, E. P., Ford, D. E., Roizen, M. F., & Roach, K. W. Preventive care guidelines: 1991. Annals of Internal Medicine. 114:758-783. [pmid: 2012359].
Hill, A. B Principles of medical statistics (9th ed.), New York: . Oxford University Press, pp. 309 323
Kleinbaum, D. G., Kupper, L. L., & Morgenstern, H Epidemiological research: Principles and quantitative methods , Belmont, , CA: . Lifetime Learning Publications.
Koepsell, T. D., Wagner, E. H., Cheadle, A. C., Patrick, D. L., Martin, D. C., Diehr, P. H., Perrin, E. B., Kristal, A. R., Allan-Andrilla, C. H., & Dey, L. J. Selected methodological issues in evaluating community-based health promotion and disease prevention programs. Annual Review of Public Health. 13:31-57.
Windsor, R. A., Baranowski, T., Clark, N., & Cutter, G Evaluation of health promotion and education programs. , Mountain View, , CA: . Mayfield Publishing Company.