# Research and Practice Information Search Protocols

## Research Information Search

### Protocol for Identifying Research Evidence

Following the direction of the Planning Group, the chair of the expert panel and PEPS staff prepared a prospectus that defines the scope of the guide.

PEPS staff conducted database searches on the following keywords:

- Alcohol
- Alcohol availability
- Alcohol outlets
- Alcohol retailing
- Environmental prevention
- Liquor
- Responsible beverage service
- Responsible hospitality.

Databases searched for the keywords included the following:

- Current Contents
- ERIC
- Excerpta Medica
- Health Periodicals Database
- MEDLINE
- NTIS
- PsychInfo
- Public Affairs Information Service.

PEPS staff prepared an annotated bibliography of applicable research identified through these database searches and retrieved the relevant articles.

The Federal resource panel and the expert panel reviewed the prospectus and bibliography and recommended further searches on the following prevention approaches:

- Age restrictions on sales
- Alcohol outlet density
- Beverage characteristics
- Conditions of alcohol sales
- Enforcement
- Environmental design
- Hours and days of alcohol sales
- Monopoly versus private alcohol sales
- Prices and taxes.

PEPS staff conducted additional database searches on the above approaches and retrieved the relevant articles. The references in the retrieved literature were reviewed for other applicable citations. Procedures for accessing fugitive literature were discussed at the expert panel meeting, then such material was retrieved accordingly.

In all, 231 articles were retrieved and reviewed. Those meeting the criteria of relevancy to the topic and of having applications for an intervention or policy to reduce problems related to alcohol availability were annotated and organized by approach. The Alcohol Expert Panel subgroup reviewed the articles and determined that 65 of them would be included in the guide.

## Practice Information Search

### Protocol for Soliciting Practice Evidence

Single State Agency directors, State National Prevention Network designees, and State Alcoholic Beverage Control boards were each sent a letter requesting State information on community-based alcohol-related problem prevention programs that focus on alcohol availability. The letter included a short nomination form requesting contact information for practice projects (see page 133) and a longer nomination form requesting specific project information.

Other groups that received requests for nominations included the following:

- American Planning Association
- Mothers Against Drunk Driving
- National Association of Chiefs of Police
- National Association of Counties
- National Council on Alcoholism and Drug Dependence
- National League of Cities
- National Sheriffs' Association
- Police Executive Research Forum
- Urban Institute
- U.S. Conference of Mayors

Follow-up phone calls were made to the State alcohol-control contacts to ask them to return the nomination forms. All but four States responded to the request. Follow-up faxes requesting project information were sent to all nominated contact persons. All nominated projects were reviewed. Those meeting the following criteria were selected for annotation:

- Adequate documentation to annotate the project
- Clearly stated objectives
- Definition and description of the intervention
- Outcome evaluation information
- Process evaluation documentation

In all, 64 programs were reviewed; 13 are included in the guide. Those projects that met the criteria were annotated and organized by approach. The annotations were reviewed by the Alcohol Expert Panel subgroup for inclusion in the guide.

Practice Evidence Nomination Form
Criteria for PEPS Program Review/Triage (Please check all questions that apply.) | Yes | No | Do Not Know
Planning/Rationale Was a community/group needs assessment conducted? Were specific research findings/concepts used as a basis for program planning?
Program Design Are objectives clearly documented? Are selected strategies/activities explicitly related to stated objectives?
Documentation Is there a system in place for documenting implementation and operations? For documenting outcomes? Are progress reports, program assessments, and evaluation results available? Are training materials and/or operations manuals available?
Evaluation/Outcomes If program has ended: Did the program achieve desired outcomes or related positive outcomes? If program has not ended: Are there specific plans to assess outcomes?
Replication Does the program show promise for replication? Has this program been replicated?