# References

DiFranza, J.R.; Richards, J.W.; Paulman, P.M.; Wolf-Gillespie, N.; Fletcher, C.; Jaffe, R.D.; and Murray, D. RJR Nabisco's cartoon camel promotes Camel cigarettes to children. Journal of the American Medical Association. 1991;266(22):3149-3153. [pmid: 1956102].
Fischer, P.M.; Schwartz, M.P.; Richards, J.W.; Goldstein, A.O.; and Rojas, T.H. Brand logo recognition by children aged 3 to 6 years. Journal of the American Medical Association. 1991;266(22):3145-3148. [pmid: 1956101].
Institute of Medicine. Growing Up Tobacco Free: Preventing Nicotine Addiction in Children and Youths. Lynch, B.S., and Bonnie, R.J., eds. Washington, D.C.: National Academy Press, 1994.
Johnston, L.; O'Malley, P.; and Bachman, J. National Survey Results on Drug Use from the Monitoring the Future Study, 1975--1993. NIH Pub. No. 94--3809. Washington, D.C.: Supt. of Docs., U.S. Govt. Print. Off., 1994.
U.S. Department of Health and Human Services. Healthy People 2000. National Health Promotion and Disease Prevention Objectives. DHHS Pub. No. (PHS) 91--50212. Washington, D.C.: Supt. of Docs., U.S. Govt. Print. Off., 1990.
U.S. Department of Health and Human Services. Preventing Tobacco Use Among Young People: A Report of the Surgeon General. DHHS Pub. No. (CDC)94--0111. Atlanta, Georgia: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Office on Smoking and Health, 1994.