# Research and Practice Evidence Analyzed

## Economic Interventions

### Research Evidence

Glantz, S.A. Changes in cigarette consumption, prices, and tobacco industry revenues associated with California's Proposition 99. Tobacco Control. 1993;2:311-314.
Peterson, D.E.; Zeger, S.L.; Remington, P.L.; and Anderson, H.A. The effect of State cigarette tax increases on cigarette sales, 1955 to 1988. American Journal of Public Health. 1992;82:94-96. [pmid: 1536343].
United States General Accounting Office. Teenage Smoking: Higher Taxes Should Significantly Reduce the Number of Smokers: Report to the Honorable Michael A. Andrews, House of Representatives. GAO Pub. No. 89--119. Washington, D.C.: U.S. General Accounting Office, 1989.
Warner, K.E. Smoking and health implications of a change in the federal cigarette excise tax. Journal of the American Medical Association. 1986;255:1028-1032. [pmid: 3945014].

## Counteradvertising

### Research Evidence

Bauman, K.E.; LaPrelle, J.; Brown, J.D.; Koch, G.G.; and Padgett, C.A. The influence of three mass media campaigns on variables related to adolescent cigarette smoking: Results of a field experiment. American Journal of Public Health. 1991;81:597-604. [pmid: 2014859].
Flynn, B.S.; Worden, J.K.; Secker-Walker, R.H.; Badger, G.J.; Geller, B.M.; and Costanza, M.C. Prevention of cigarette smoking through mass media intervention and school programs. American Journal of Public Health. 1992;82:827-834. [pmid: 1585963].
Flynn, B.S.; Worden, J.K.; Secker-Walker, R.H.; Pirie, P.L.; Badger, G.J.; Carpenter, J.H.; and Geller, B.M. Mass media and school interventions for cigarette smoking prevention: Effects 2 years after completion. American Journal of Public Health. 1994;84:1148-1150. [pmid: 8017542].
McKenna, J.W., and Williams, K.N. Crafting effective tobacco counteradvertisements: Lessons from a failed campaign directed at teenagers. Public Health Reports. 1993;108 (Supp.1):85-89. [pmid: 8210278].
Murray, D.M.; Prokhorov, A.V.; and Harty, K.C. Effects of a Statewide antismoking campaign on mass media messages and smoking beliefs. Preventive Medicine. 1994;23:54-60. [pmid: 8016033].
Popham, W.J.; Potter, L.D.; Hetrick, M.A.; Muthen, L.K.; Duerr, J.M.; and Johnson, M.D. Effectiveness of the California 1990--1991 Tobacco Education Media Campaign. American Journal of Preventive Medicine. 1994;19(6):319-326. [pmid: 7880550].

## Retailer-Directed Interventions

### Cluster 1: Research Evidence

Altman, D.G.; Foster, V.; Rasenick-Douss, L.; and Tye, J.B. Reducing the illegal sale of cigarettes to minors. Journal of the American Medical Association. 1989;261:80-83. [pmid: 2908999].
Altman, D.G.; Rasenick-Douss, L.; Foster, V.; and Tye, J.B. Sustained effects of an educational program to reduce sales of cigarettes to minors. American Journal of Public Health. 1991;81:891-893. [pmid: 2053666].
Biglan, A.; Henderson, J.; Humphreys, D.; Yasui, M.; Whisman, R.; Black, C.; and James, L. "Experimental Evaluation of a Community Intervention to Reduce Youth Access to Tobacco." Unpublished manuscript, 1994a.
Keay, K.D.; Woodruff, S.I.; Wildey, M.B.; and Kenney, E.M. Effects of a retailer intervention on cigarette sales to minors in San Diego County, California. Tobacco Control. 1993;2:145-151.
Skretny, M.T.; Cummings, K.M.; Sciandra, R.; and Marshall, J. An intervention to reduce the sale of cigarettes to minors. New York State Journal of Medicine. 1990;90:54-55. [pmid: 2304661].
Wildey, M.B.; Woodruff, S.I.; Agro, A.; Keay, K.D.; Kenney, E.M.; and Conway, T.L. Sustained effects of educating retailers to reduce cigarette sales to minors. Public Health Reports. 110:625-629.

### Cluster 1: Practice Evidence

[no author listed]. The Tobacco-Free Youth Project of the COMMIT to a Healthier Raleigh Project: Raleigh, North Carolina.

### Cluster 2: Research Evidence

Forster, J.L.; Hourigan, M.E.; and Kelder, S. Locking devices on cigarette machines: Evaluation of a city ordinance. American Journal of Public Health. 1992a;82:1217-1219. [pmid: 1503160].
Forster, J.L.; Hourigan, M.; and McGovern, P. Availability of cigarettes to underage youth in three communities. Preventive Medicine. 1992b;21:320-328. [pmid: 1614994].
Hinds, M.W. Impact of a local ordinance banning tobacco sales to minors. Public Health Reports. 1992;107:355-358. [pmid: 1594748].
Jason, L.A.; Ji, P.Y.; Anes, M.D.; and Birkhead, S.H. Active enforcement of cigarette control laws in the prevention of cigarette sales to minors. Journal of the American Medical Association. 1991;266:3159-3161. [pmid: 1956104].

### Cluster 3: Research Evidence

Feighery, E.; Altman, D.G.; and Shaffer, G. The effects of combining education and enforcement to reduce tobacco sales to minors: A study of four northern California communities. Journal of the American Medical Association. 1991;266:3168-3171. [pmid: 1956106].
Jason, L.A.; Ji, P.Y.; Anes, M.D.; and Birkhead, S.H. Active enforcement of cigarette control laws in the prevention of cigarette sales to minors. Journal of the American Medical Association. 1991;266:3159-3161. [pmid: 1956104].

### Cluster 3: Practice Evidence

The Dover Youth Access to Tobacco Reduction Program of the Dover Police Department: Dover, New Hampshire. The Pajaro Valley Prevention and Student Assistance program of the Pajaro Valley Unified School District: Wastonville, California. The Project SCAN (Stop Children's Addiction To Nicotine): Erie County, New York. The Stop Tobacco Access for Minors Project of the North Bay Health Resources Center: Sonoma County, California. The Stop Teenage Addiction to Tobacco program of Stanford University School of Medicine: San Jose, California.

## Multicomponent School-Linked Community Approaches

### Cluster 1: Research Evidence

Biglan, A.; Ary, D.; Yudelson, H.; Duncan, T.; Hood, D.; James, L.; Koehn, V.; Wright, Z.; Black, C.; Levings, D.; Smith, S.; and Gaiser, E. "Experimental Evaluation of a Modular Approach to Media Campaigns for the Prevention of Adolescent Tobacco Use." Unpublished manuscript, 1994d.
Flay, B.R.; Hansen, W.B.; Johnson, C.A.; Collins, L.M.; Dent, C.W.; Dwyer, K.M.; Grossman, L.; Hockstein, G.; Rauch, J.; Sobel, J.L.; Sobel, D.F.; Sussman, S.; and Ulene, A. Implementing effectiveness trial of a social influences smoking prevention program using schools and television. Health Education Research. 1987;2:385-400.
Pentz, M.A.; MacKinnon, D.P.; Dwyer, J.H.; Wang, E.Y.I.; Hansen, W.B.; Flay, B.R.; and Johnson, C.A. Longitudinal effects of the Midwestern Prevention Project on regular and experimental smoking in adolescents. Preventive Medicine. 1989a;18:304-321. [pmid: 2740299].
Pentz, M.A.; MacKinnon, D.P.; Flay, B.R.; Hansen, W.B.; Johnson, C.A.; and Dwyer, J.H. Primary prevention of chronic diseases in adolescence: Effects of the Midwestern Prevention Project on tobacco use. American Journal of Epidemiology. 1989b;130:713-724. [pmid: 2788994].
Perry, C.L.; Crockett, S.J.; and Pirie, P. Influencing parental health behavior: Implications of community assessments. Health Education. 1987;October/November.
Perry, C.L.; Pirie, P.; Holder, W.; Halper, A.; and Dudovitz, B. Parent involvement in cigarette smoking prevention: Two pilot evaluations of the "Unpuffables Program.". Journal of School Health. 1990;60:443-447. [pmid: 2283873].
Stevens, M.M.; Youells, F.E.; Freeman, D.H.; Linsey, S.C.; and Mott, L.A. Smokeless tobacco use among children: The New Hampshire Study. American Journal of Preventive Medicine. 1993;9:160-167. [pmid: 8347367].
Werch, C.E.; Young, M.; Clark, M.; Garrett, C.; Hooks, S.; and Kersten, C. Effects of a take-home drug prevention program on drug-related communication and beliefs of parents and children. Journal of School Health. 1991;61:346-350. [pmid: 1787697].

### Cluster 1: Practice Evidence

The Multicultural Area Health Education Center project: East Los Angeles, California.

### References

Biglan, A.; Ary, D.; Yudelson, H.; Duncan, T.; Hood, D.; James, L.; Koehn, V.; Wright, Z.; Black, C.; Levings, D.; Smith, S.; and Gaiser, E. "Experimental Evaluation of a Modular Approach to Media Campaigns for the Prevention of Adolescent Tobacco Use." Unpublished manuscript, 1994b.
Edwards, C.C.; Elder, J.P.; de Moor, C.; Wildey, M.B.; Mayer, J.A.; and Senn, K.L. Predictors of participation in a school-based anti-tobacco activism program. Journal of Community Health. 1992;17:283-289. [pmid: 1401235].
Elder, J.P.; Sallis, J.F.; Woodruff, S.I.; and Wildey, M.B. Tobacco-refusal skills and tobacco use among high-risk adolescents. Journal of Behavioral Medicine. 1993;16:629-642. [pmid: 8126716].

### Cluster 2: Practice Evidence

The Health Is Wealth project of the Asian Health Services: Oakland, California.

### References

Biglan, A.; Ary, D.; Yudelson, H.; Duncan, T.; Hood, D.; James, L.; Koehn, V.; Wright, Z.; Black, C.; Levings, D.; Smith, S.; and Gaiser, E. "Experimental Evaluation of a Modular Approach to Media Campaigns for the Prevention of Adolescent Tobacco Use." Unpublished manuscript, 1994c.
Flay, B.R.; Hansen, W.B.; Johnson, C.A.; Collins, L.M.; Dent, C.W.; Dwyer, K.M.; Grossman, L.; Hockstein, G.; Rauch, J.; Sobel, J.L.; Sobel, D.F.; Sussman, S.; and Ulene, A. Implementing effectiveness trial of a social influences smoking prevention program using schools and television. Health Education Research. 1987;2:385-400.
Flynn, B.S.; Worden, J.K.; Secker-Walker, R.H.; Badger, G.J.; Geller, B.M.; and Costanza, M.C. Prevention of cigarette smoking through mass media intervention and school programs. American Journal of Public Health. 1992;82:827-834. [pmid: 1585963].
Flynn, B.S.; Worden, J.K.; Secker-Walker, R.H.; Pirie, P.L.; Badger, G.J.; Carpenter, J.H.; and Geller, B.M. Mass media and school interventions for cigarette smoking prevention: Effects 2 years after completion. American Journal of Public Health. 1994;84:1148-1150. [pmid: 8017542].
Pentz, M.A.; MacKinnon, D.P.; Dwyer, J.H.; Wang, E.Y.I.; Hansen, W.B.; Flay, B.R.; and Johnson, C.A. Longitudinal effects of the Midwestern Prevention Project on regular and experimental smoking in adolescents. Preventive Medicine. 1989a;18:304-321. [pmid: 2740299].
Pentz, M.A.; MacKinnon, D.P.; Flay, B.R.; Hansen, W.B.; Johnson, C.A.; and Dwyer, J.H. Primary prevention of chronic diseases in adolescence: Effects of the Midwestern Prevention Project on tobacco use. American Journal of Epidemiology. 1989b;130:713-724. [pmid: 2788994].