# Conclusions

This practitioner's guide is intended to be brief and simple. Much of the detail concerning the analysis of these prevention approaches, as well as a history of tobacco use in the United States, the epidemiology of tobacco use among youth, and recommendations for implementation of the approaches described here, can be found in the parent document, Reducing Tobacco Use Among Youth: Community-Based Approaches. The reader is referred to the parent guideline for a full treatment of these issues. Both documents bring you a first-of-its-kind set of guidelines for practitioners based on the PEPS systematic analysis of the effectiveness of interventions. These guidelines are intended to be clear, realistic, and relatively easy to use. It is hoped that they will help develop markedly more effective tobacco-reduction programs for youth.