# What Works? Six PEPS Prevention Approaches

A prevention approach is a collection of prevention activities that broadly share common methods and strategies, assumptions (theories or hypotheses), and outcomes. The six prevention approaches summarized here are:

- Economic Interventions
- Counteradvertising
- Retailer-Directed Interventions
- Multicomponent School-Linked Community Approaches
- Tobacco-Free Environment Policies
- Restriction of Advertising and Promotion

Two of the six prevention approaches were sufficiently broad to have identifiable subsets, each with its own emphasis or focus. These subsets of prevention approaches are referred to as clusters. Practitioners are encouraged to refer to the comprehensive guideline for a detailed description of these six approaches. The following pages present a brief description of each prevention approach and highlights of the conclusions drawn from the evidence.

## Prevention Approach 1: Economic Interventions

The primary goals of economic interventions as a prevention approach are to raise the price of tobacco products through increased taxes and thereby prevent youth from taking up smoking, delay the age at which they might begin, and decrease the level of tobacco consumption.

### Rationale

Adolescents, who have limited financial resources, are sensitive to price increases. Higher prices should reduce the likelihood of adolescent tobacco purchases.

### Objectives of the Studies Reviewed

- To determine whether adolescent demand for cigarettes fluctuates in response to decreases and increases in the Federal excise tax
- To compare trends in tobacco consumption in States where there are tax increases with trends in States where there are no tax increases
- To identify the effect of increases in Federal tobacco excise taxes on the number of adolescent smokers

### Activities of the Studies Reviewed

- Increase in taxes on cigarettes through the Federal legislative process
- Increase in taxes on cigarettes through State legislation

Level of Evidence

The research evidence reviewed indicates that laws can be established or modified to increase Federal or State taxes on tobacco products:

There is strong evidence that instituting tobacco tax increases is an effective approach to reduce the prevalence of adolescent tobacco use--especially when the tax is sufficiently hight and is linked to the consumer price index.

### Lessons Learned From Reviewed Evidence

- Tobacco tax increases are effective in reducing the prevalence of tobacco use by adolescents. Efforts to increase State taxes on tobacco products have included the mobilization of community groups, other groups, and legislators. Depending on the State, taxes can be increased through either the initiative or the legislative process.
- Although tobacco tax increases will decrease the prevalence of adolescent tobacco use, other prevention activities must be utilized to sustain such decreases. Tobacco tax increases are most effective within a comprehensive, multicomponent prevention program.
- The benefits of increases in tobacco taxes, such as reduction in adolescent cigarette use, will shrink as inflation erodes the real value of the tax increase
- unless the excise tax is indexed so that the nominal tax rate (expressed in cents per pack) rises in step with prices. Indexing tobacco taxes to the consumer price index or to the wholesale price of cigarettes would make permanent the public health gains of higher taxes.

## Prevention Approach 2: Counteradvertising

The primary goal of counteradvertising is to change perceived norms among children and adolescents regarding tobacco use.

### Rationale

Research and experience demonstrate that adolescents develop attitudes, beliefs, and behaviors regarding tobacco use from peers, family members, television, and other cultural sources. Adolescents often think that tobacco use is more widespread and universally acceptable than it actually is. Advertising links tobacco use with peer acceptance, success, and good times. Media messages that promote negative images about tobacco use, reveal the number of teens who actually use tobacco, and address the unacceptableness of tobacco use should help change these perceived norms.

### Objectives of the Studies Reviewed

- To increase exposure of children and adolescents to negative messages about using tobacco or to increase positive messages about not using tobacco
- To increase adolescents' ability to identify hidden messages (e.g., "If you smoke, you're cool") in tobacco advertising
- To increase young people's awareness of tobacco industry marketing tactics
- To improve adolescents' tobacco refusal skills
- To encourage adolescents to quit smoking

### Activities of the Studies Reviewed

- Radio and television campaigns
- Multilevel media campaigns that include billboards, posters, magazines, radio, and television
- A mass-media campaign linked to a school-based prevention intervention
- Airing of antitobacco media campaigns on prime-time television

Level of Evidence

The research evidence reviewed indicates that it is possible to implement counteradvertising interventions:

- There is strong evidence that counteradvertising is effective in changing the attitudes of adolescents about tobacco use.
- There is medium evidence that counteradvertising is effective in reducing adolescent tobacco use.

### Lessons Learned From Reviewed Evidence

- Counteradvertising, in the form of multicomponent media-based prevention efforts, can have an effect on youth with regard to awareness of media campaigns, decreased smoking prevalence, and nonsmokers' decreased intention to start. These efforts demonstrate the ability to result in increased negative attitudes toward smoking, an increased understanding of the consequences of smoking, and decreased rates of friends' approval of smoking.
- Multicomponent prevention efforts are more effective than single-component prevention programs. Media campaigns have been shown to support and promote other components and vice versa. Effective media campaigns involve linkages with other intervention activities.
- To be effective, media messages should be age appropriate and designed with the target audience's developmental stage in mind. In particular, messages should not be too subtle or too sophisticated.

## Prevention Approach 3: Retailer-Directed Interventions

The primary goal of tobacco retailer-directed interventions is to reduce tobacco sales to minors and tobacco purchases by minors. Within this approach, research and practice is divided into three clusters: merchant and community education about adolescent tobacco use and laws prohibiting tobacco sales to minors, enactment of laws prohibiting tobacco sales to minors, and enforcement of laws prohibiting tobacco sales to minors combined with merchant and community education about adolescent tobacco use and the laws prohibiting tobacco sales to minors.

### Cluster 1: Merchant and Community Education About Adolescent Tobacco Use and the Laws Prohibiting Tobacco Sales to Minors

#### Rationale

Research demonstrates that adolescents can easily purchase tobacco products in convenience stores, grocery stores, service stations, and pharmacies. Educating merchants, clerks, and community members about adolescent tobacco use and the laws prohibiting tobacco sales to minors should reduce the likelihood of sales to minors.

#### Objectives of the Studies Reviewed

- To determine whether education programs aimed at merchants and the community at large reduce the sale of tobacco products to minors
- To determine whether offering positive reinforcement to clerks and merchants for not selling tobacco to minors reduces tobacco sales to minors
- To determine whether asking for proof of age reduces tobacco sales to minors

#### Activities of the Studies Reviewed

- Educate clerks and merchants about adolescent tobacco problems, existing laws prohibiting tobacco sales to minors, and their responsibility for complying with these laws.
- Educate the public, community groups, and mass media about adolescent tobacco problems and existing laws prohibiting tobacco sales to minors.
- Enlist community support for and involvement in educational interventions.
- Monitor and publicize the results of attempts made by adolescents to purchase tobacco.
- Provide warning signs in retail stores about laws prohibiting tobacco sales to minors.

Level of Evidence

The research and practice evidence reviewed indicates that interventions can be designed to provide merchant and community education about adolescent tobacco use and the laws prohibiting tobacco sales to minors:

There is medium evidence that combined merchant and community education results in a short-term decrease in over-the-counter tobacco sales to minors.

### Cluster 2: Enactment of Laws To Prohibit Tobacco Sales to Minors

#### Rationale

Research demonstrates that adolescents can easily purchase tobacco products in convenience stores, grocery stores, service stations, and pharmacies. They can easily purchase cigarettes from vending machines. Enacting laws prohibiting over-the-counter and vending machine tobacco sales to minors should reduce the likelihood of tobacco sales to them.

#### Objectives of the Studies Reviewed

- To determine whether enacting laws to restrict tobacco sales to minors and increasing penalties for merchants who violate these laws will result in a change in merchants' attitudes and behaviors
- To determine whether an ordinance restricting tobacco sales to minors has an effect on sales to them
- To determine whether an ordinance that mandates locking devices on cigarette machines will decrease machine sales of cigarettes to minors

#### Activities of the Studies Reviewed

- Enact local ordinances restricting the sale of tobacco to minors.
- Place cigarette vending machines in locations inaccessible to minors.
- Require locking devices on cigarette vending machines that merchants must unlock for a purchase to occur.
- Require merchant licenses for vending machines.
- Require merchant licenses for over-the-counter sales of tobacco products.
- Require merchants to ask for proof of age when a customer appears to be underage.
- Require that merchants post warning signs about laws restricting tobacco sales to minors.
- Enact civil penalties (for example, suspension or revocation of licenses) for violating laws restricting tobacco sales to minors.

Level of Evidence

The research reviewed indicates that laws can be written and established that increase the penalties for selling tobacco to minors:

There is substantial evidence of the ineffectiveness of enacting ordinances requiring locking devices on cigarette machines. These ordinances are ineffective because merchants see locking as a burden and frequently leave the devices unlocked. Law enforcement officials accord a low priority to these infractions.

There is medium evidence that laws increasing penalties for tobacco sales to minors have a short-term effect on reducing over-the-counter tobacco sales to minors.

### Cluster 3: Enforcement of Laws Prohibiting Tobacco Sales to Minors Plus Merchant and Community Education About Adolescent Tobacco Use and the Laws Prohibiting Tobacco Sales to Adolescents

#### Rationale

Research demonstrates that adolescents can easily purchase tobacco products in convenience stores, grocery stores, service stations, and pharmacies. They can easily purchase cigarettes from vending machines. A comprehensive effort to enact and enforce laws prohibiting tobacco sales to minors, in addition to educating merchants, clerks, and the community about these laws and about adolescent tobacco use, should reduce the likelihood of tobacco sales to minors.

#### Objectives of the Studies Reviewed

- To determine whether enforcement of laws prohibiting tobacco sales, combined with merchant and community education about adolescent tobacco use and the laws prohibiting sales to minors, will decrease sales of tobacco products to minors over the long term
- To determine whether an enforcement component in combination with a community education intervention has greater impact than an education program alone

#### Activities of the Studies Reviewed

- Seek and secure community partnership, support, and sponsorship of prevention activities.
- Establish the rate of tobacco sales to minors by monitoring purchase attempts.
- Visit merchants to educate them about the laws prohibiting sales to minors and the consequences of noncompliance.
- Have youth and law enforcement personnel work together to deliver merchant education materials (for example, tips on how to refuse sales to minors, warning signs, fact sheets).
- Monitor and publicize the results of adolescents' attempts to purchase tobacco products.
- Provide positive reinforcement (for example, financial rewards, product incentives, media recognition) to merchants who refuse to sell tobacco to adolescents.
- Hold press conferences and similar events to publicize activities.

Level of Evidence

The research and practice evidence reviewed indicates that it is possible to implement prevention programs that combine merchant and community education with law enforcement components:

There is medium evidence that combined merchant and community education with enforcement of the law will reduce over-the-counter tobacco sales to minors. However, because most localities have only recently enhanced their education and enforcement efforts, there is insufficient evidence to conclude that this effect will be sustained over a long period of time.

#### Lessons Learned From Reviewed Evidence

- Merchant education is a valuable component of community-based prevention strategies. Although merchant education as an independent component of prevention may not cause robust results by itself, it appears to enhance the effect of other prevention components.
- Similarly, merchant education in the context of a multicomponent community-based prevention program helps to increase promotion of community involvement. It can help merchants to understand their role in community prevention efforts and to perceive themselves as community partners. Merchant education helps other community partners to understand the roles and responsibilities of merchants in a community partnership and diminishes the likelihood of viewing cigarette merchants as adversaries.
- There is a continuum of effect as a result of increasing the intensity of interventions; that is, the passing of a law prohibiting tobacco sales to minors without any other interventions will have the least effect. The intervention effect is optimized when there are several components, namely: (1) enacting laws prohibiting tobacco sales to minors, (2) enforcing these laws through publicized purchase attempts with police sponsorship or cooperation, (3) educating merchants and the community about adolescent tobacco use and the laws prohibiting tobacco sales to minors, (4) seeking comprehensive community support of these prevention efforts, and (5) education of and cooperation with judges to impose consequences on violators of the tobacco access laws.
- Adolescents can take an active role in education and prevention efforts with adults. They can be effective as partners in educating members of the legislature, local judges, and local organizations and agencies. In particular, adolescents can work as partners with law enforcement during merchant education efforts.
- Decreased sales of tobacco to youth within a given community are not necessarily indicative of decreased availability or accessibility to youth, because adolescents may be able to obtain tobacco in nearby communities. The real-world effects of these efforts should be considered on the target population as well as on nearby communities.

## Prevention Approach 4: Multicomponent School-Linked Community Approaches

The primary goal of this prevention approach is to discourage adolescent tobacco use by mobilizing community systems through school-based programs. Within this prevention approach, the research and practice evidence is divided into three clusters each with its own emphasis: parent involvement, student antitobacco activism, and media interventions.

### Cluster 1: Parent Involvement

#### Rationale

Research demonstrates that multicomponent programs are more effective than single-component interventions for preventing tobacco use among adolescents. Adding parental involvement to a school-based prevention program should therefore increase the effectiveness of the school-based program.

#### Objectives of the Studies Reviewed

- To expose parents to antitobacco messages through multiple channels
- To increase parents' knowledge about tobacco problems and antitobacco attitudes and beliefs
- To increase parents' awareness of, receptivity to, and participation in smoking prevention efforts
- To encourage parents to discuss tobacco-related issues with their children
- To help families develop rules regarding tobacco use in the home
- To determine whether adding a parental component increases the effectiveness of school-based antitobacco programs
- To enlist parents in influencing the attitudes of educators and school administrators about adolescents' tobacco problems
- To help parents strengthen their children's refusal skills and to change family norms to nonuse of tobacco

#### Activities of the Studies Reviewed

- Parent surveys
- Take-home quizzes for parents and students
- Letters to parents
- Smoking cessation services and self-help materials for parents
- Television segments on smoking prevention and cessation
- Pamphlets for parents containing information about teen tobacco problems
- Educational materials for parents with tips on how to encourage their kids not to smoke
- Parent training
- Community organizing to develop school policies discouraging tobacco use and to institute drug prevention curricula
- Community organizing to promote community change regarding use of alcohol, tobacco, and illicit drugs by adolescents
- Media campaigns to support other program components

Level of Evidence

The research and practice evidence reviewed indicates that it is possible to implement multicomponent prevention programs that combine parental involvement components with other prevention efforts, such as school-based programs:

- There is medium evidence that multicomponent, school-linked programs with a parental component promote (1) improved parental knowledge about adolescent tobacco use, (2) the development of negative attitudes by parents toward tobacco use, and (3) the mobilization of parents to speak with their children about not using tobacco.
- There is medium evidence that these programs change students' perceptions regarding tobacco use.

### Cluster 2: Student Antitobacco Activism

#### Rationale

Research demonstrates that multicomponent programs are more effective than single-component interventions in preventing tobacco use among adolescents. Adding student antitobacco activism as a component to a school-based prevention program should, therefore, increase the effectiveness of the school-based program. Student antitobacco activism is defined as participation in planned and structured activities designed to raise awareness, provide education, or prompt social changes relating to tobacco use among youth.

#### Objectives of the Studies Reviewed

- To increase students' knowledge of problems associated with tobacco use
- To promote antitobacco education and attitudes among peers
- To teach students how to encourage their parents and others to quit smoking
- To create an antitobacco environment
- To counteract the promotional efforts of the tobacco industry
- To encourage students to play a prominent role in developing messages and designing activities that will have a positive effect on their peers
- To determine whether activism components attract and affect students at high risk for tobacco use

#### Activities of the Studies Reviewed

- Writing letters to:
  - Members of a favorite sports team, asking them not to use or endorse tobacco products - A restaurant manager or owner, advocating smoke-free restaurants - Film producers and magazine editors protesting tobacco advertising
- Holding poster contests
- Creating antitobacco art projects
- Making floats and participating in community parades and festivals
- Writing and singing antitobacco songs
- Revising school policies regarding tobacco use
- Planning and attending a culturally specific youth health day
- Designing and painting an antitobacco mural at a junior high school
- Participating in the production of antitobacco animated videos, in debates regarding tobacco issues, and in the development of a smoking education curriculum

Level of Evidence

The research and practice evidence reviewed indicates that it is possible to implement prevention programs that involve student activism:

- There is medium evidence that adolescents can be mobilized to participate in antitobacco activism within schools and the community.
- There is medium evidence that student activism is effective in improving adolescents' knowledge about tobacco and in promoting negative attitudes regarding tobacco use.
- There is suggestive but insufficient evidence that student activism is effective in preventing adolescent tobacco use because few studies have assessed this outcome.

### Cluster 3: Media Interventions

#### Rationale

Research demonstrates that multicomponent programs are more effective than single-component interventions in preventing tobacco use among adolescents. Adding media-based interventions to a school-based prevention program should therefore increase the effectiveness of the school-based program.

#### Objectives of the Studies Reviewed

- To disseminate information about the hazards of tobacco use and the use of marketing techniques by the tobacco industry
- To counteract the influence of media campaigns by the tobacco industry
- To assess the effects of a print media campaign directed at adolescents and their parents
- To increase parents' negative attitudes toward adolescent tobacco use
- To provide adolescents with knowledge and skills to resist peer, family, and media influences to use tobacco
- To determine whether adding mass-media interventions to a school-based prevention program enhances the impact of the school program

#### Activities of the Studies Reviewed

- Mass-media events such as press conferences, interviews, talk shows, and articles
- Daily 5-minute television segments featuring smoking prevention that are coordinated with school curricula
- Curricula and other written information on the hazards of tobacco use for students, teachers, and parents
- Mass-media antitobacco advertisements and public service announcements

Level of Evidence

The research evidence reviewed indicates that it is possible to develop adolescent tobacco use prevention programs utilizing media components in combination with othe rprevention efforts (such as school-based programs):

- There is medium evidence that exposure to media-based antitobacco interventions, in concert with school-based tobacco education, can change adolescent students' knowledge, attitudes, and beliefs about tobacco use and industry marketing practices.
- There is medium evidence that multicomponent prevention programs that include media-based interventions are effective in preventing adolescent tobacco use.

#### Lessons Learned From Reviewed Evidence

- Programs designed to enhance the effectiveness of school-based curricula result in increased family and student attention to antitobacco messages. However, there is limited evidence that these programs reduce tobacco use among youth.
- The effects of a fully implemented school- and community-based intervention (including parental involvement) to reduce adolescent tobacco use as part of a broader substance abuse prevention strategy may be limited by the community's view of tobacco use as a minor issue in relation to other forms of substance abuse and the likelihood that addressing adolescent tobacco use will not be considered a priority.
- The effectiveness of multicomponent prevention programs may be related to the multiplicative effect, that is, the net effect of a program may be greater than the sum of the individual effects of the program components. In other words, the ways in which program components interact with each other and their effects on each other are largely unknown. As a result, it may not be feasible to assess the independent contributions of each component.
- Students who voluntarily participate in school-based antitobacco activism projects may not be at high risk for using tobacco. The program, therefore, may be focused disproportionately on those who are already at low risk.

## Prevention Approach 5: Tobacco-Free Environment Policies

The primary goal of tobacco-free environmental policies is to create environments that do not expose youth to the use and possession of tobacco.

### Rationale

Research demonstrates that tobacco use and exposure to secondhand tobacco smoke is a threat to health. Policies restricting the use of tobacco in schools and other environments should reduce adolescents' exposure to secondhand tobacco smoke and limit places where they can use tobacco and thus reduce the health risks associated with tobacco use and secondhand smoke.

### Objectives of the Studies Reviewed

- To develop and implement policies restricting or prohibiting tobacco use by adolescents and adults in recreational, school, and work settings
- To evaluate the effectiveness of policies restricting tobacco use on rates of adolescent smoking
- To provide information and services that will assist individuals to develop and comply with policies restricting tobacco use

### Activities of the Studies Reviewed

- Review existing laws and compliance with laws restricting tobacco use in certain settings
- Review the effects of antismoking school policies on adolescent smoking
- Provide technical assistance and guidance on developing and implementing tobacco-free policies and environments
- Educate and inform concerned parties about laws restricting tobacco use in certain settings

### Lessons Learned From Reviewed Evidence

- The establishment of smoking regulations can be accomplished through a variety of mechanisms, including State and local laws, and policies at businesses, schools, and child-care centers. Comprehensive policies can decrease prevalence rates, especially when their emphasis is on prevention and cessation.
- Harsh penalties for the possession of tobacco products by minors, such as suspension from school, may be ineffective interventions for enhancing the enforcement of antismoking regulations or for preventing or decreasing adolescent tobacco use. Instead, programs that provide prevention or cessation services, such as tobacco education courses, tobacco cessation programs, or diversion alternatives, may be most effective.

Level of Evidence

The research and practice evidence reviewed indicates that it is possible to implement policies restricting tobacco use in schools and child day-care centers:

There is medium evidence that it is possible to influence organizations to develop policies restricting the use, possession, and exposure to tobacco among adolescents and adults. Because changes in policies regarding smoking are relatively recent, it is difficult to determine the ultimate effects of these changes on adolescent tobacco use.

## Prevention Approach 6: Restriction of Advertising and Promotion

The primary goal of this prevention approach is to decrease child and adolescent exposure to tobacco promotion and pro-tobacco influences.

### Rationale

Research demonstrates that tobacco company sales promotions are reaching adolescents and that this exposure may put them at greater risk for smoking (DiFranza et al. 1991; Fischer et al. 1991). Therefore, the reduction of youth exposure to particular types of marketing or to the quantity of marketing should reduce adolescent smoking.

### Objectives of the Studies Reviewed

- To eliminate tobacco industry sponsorship of sporting and cultural events
- To provide alternative, nontobacco industry sponsorship of these events

### Activities of the Studies Reviewed

- Provide media advocacy and the threat of adverse publicity through protesting events sponsored by the tobacco industry
- Assist event promoters by providing alternative, nontobacco funding
- Develop policies that ban tobacco industry sponsorship of sporting and cultural events
- Promote tobacco-free events
- Develop tobacco-free messages and embed them in sports education
- Advertise tobacco-free events
- Include tobacco-free messages in the event's promotional materials

### Lessons Learned From Reviewed Evidence

- The need for alternative funding is an essential component for interventions that are designed to prohibit existing and ongoing tobacco industry sponsorship of a currently active event. In particular, practitioners and community groups can develop lists of potential alternative sponsors for event promoters and be willing to actively help promoters seek alternative sponsorship. For example, local businesses that are not currently involved in sponsoring the event can be approached.
- Through the establishment of working relationships with local potential sponsors, businesses can view sponsorship of events as part of their civic responsibilities and as part of a community partnership process. In addition, existing nontobacco event sponsors may be willing to increase their level of sponsorship if there is no tobacco industry sponsorship. They may have recommendations for other potential sponsors, perhaps some of their industrial partners.

Level of Evidence

The practice evidence reviewed indicates that it is possible to implement efforts designed to eliminate tobacco sponsorship of events, to block tobacco product promotion, and to provide non-tobacco industry sponsorship of events:

- There is strong evidence that it is possible to establish policies that ban tobacco industry sponsorship of social and cultural events and influence product promotion practices.
- There is medium evidence that policies banning tobacco industry promotion of activities such as music festivals and sporting events will reduce adolescent use of tobacco.