# Criteria for Establishing Levels of Evidence of Effectiveness

The following descriptions are intentionally brief. For a more rigorous definition of the criteria, refer to the parent document Reducing Tobacco Use Among Youth: Community-Based Approaches.

## Strong Level of Evidence

Consistent results of strong or medium effect from:

- At least three studies with experimental or quasi-experimental designs

and

- The use of at least two different methodologies

OR

- Two studies with experimental or quasi-experimental designs and
- At least three case studies

## Medium Level of Evidence

Consistent positive results from:

- At least two studies with experimental or quasi-experimental designs and
- The use of at least two different methodologies

OR

- One study with experimental or quasi-experimental design and
- At least three case studies

## Suggestive but Insufficient Evidence

Research or practice evidence that:

- Is based on a plausible rationale or on previous research and
- Is being demonstrated in well-designed studies or programs currently in process
- Minimally demonstrates that the intervention being tested is linked to a positive effect.

## Substantial Evidence of Ineffectiveness

Research and practice evidence demonstrating that a prevention approach is not effective. The criterion for inclusion in this category is a statistically significant negative effect in a majority of competently done studies, including at least two quantitative studies with sample sizes sufficient to test for the significance of the effect.