# Appendices

Appendix A Criteria for Establishing Levels of Evidence of Effectiveness

Appendix B Abbreviations and Glossary

Appendix C Resource Guide