# References

Alexander, J., & Parsons, B. V.Functional family therapy
Department of Health and Human Services. (1993).Public Health Reports, 108
Emery, R. F. (1988).Marriage, divorce, and children's adjustment.
Fors, S. W., & Rojek, D. G. (1991).Journal of Drug Education, 21,
Gordon, R. (1993).Public Health Reports, 98,
Gordon, R. (1987).Preventing mental disorders
Hawkins, J. D., Catalano, R. F., & Miller, J. Y. (1992).Psychological Bulletin, 112
Herrenkohl, E. C., Herrenkohl, R. C., & Egolf, B. (1994).American Journal of Orthopsychiatry, 64
Henggeler, S. W., Rodick, J. D., Borduin, C. M., Hanson, C. L., Watson, S. M., & Urey, J. R. (1986).Developmental Psychology, 22
Henggeler, S. W., Melton, G. B., & Smith, L. A. (1992). Journal of Consulting and Clinical Psychology, 60
Kandel, D. B., & Andrews, K. (1987).International Journal of the Addictions, 22
Kinney, J., Haapala, D., Booth, C., & Leavitt, S. (1990).Reaching high-risk families: Intensive family preservation in human services.
Luthar, S. S. (1991).Child Development, 62,
Luthar, S. S., & Cushing G. (in press).Resiliency and development: Positive life adaptations.
McLanahan, S. (1988).Focus, 2
McLanahan, S., & Sandefur, G. (1994).Growing up with a single parent: What hurts, what helps.
National Center on Child Abuse and Neglect. (1994).Child maltreatment 1993: Reports from the States to the National Center on Child Abuse and Neglect.
National Institute on Drug Abuse. (1997).Monitoring the future study.
Richters, J. E., & Martinez, P. E. (1993).Development and Psychopathology, 5
Santisteban, D. A., Coatsworth, J. D., Perez-Vidal, A., Mitrani, V., Jean-Gilles, M., & Szapocznik, J. (1995).Brief structural/strategic family therapy with African American and Hispanic high-risk youth.
Turner, S., Norman E., & Zunz, S. (1993).From risk to resiliency, a paradigm shift: A literature review and annotated bibliography.
University of Michigan Institute for Social Research. (1997).Monitoring the Future Study - 1997.