# Recommendations for Practice

Following the evidence-based analysis of each approach is a special section outlining recommendations for practice. This section presents the PEPS Expert Panel members' recommendations, suggestions, observations, and interpretations regarding the prevention approach evaluated in the preceding text. General recommendations and suggestions that are applicable to more than one prevention approach appear later in the chapter.

## Types of Recommendations

The recommendations for practice vary considerably in nature and intent. Some are practical suggestions for optimal implementation of a particular intervention, while others suggest techniques and cautions to avoid problems. A few are practical observations about what to expect during certain prevention activities. Others interpret research findings or illustrate the practical context of prevention efforts. Some recommendations reflect expert opinions of the panel members, such as assumptions and hypotheses that drive certain prevention activities. Many represent "best practices" among prevention experts, while some recommendations relate to the implementation of specific prevention interventions.

## Basis of Recommendations

These recommendations are based on the research and practice evidence reviewed in the Analysis of Evidence section, additional evidence not described in the section, and the professional experience and opinions of Expert Panel members. Many recommendations are derived from the experiences of Expert Panel members involved with research or practice activities that are not explicitly described in the chapter.

These recommendations represent the transfer of practical information from prevention research and practice experts to prevention decisionmakers, such as State and local prevention authorities, other prevention practitioners and researchers, and members of community prevention organizations.