# Levels of Evidence

At the heart of the guideline development process are several concepts concerning the weight of the evidence that makes research or practice information strong enough to serve as the basis for recommendations. As these concepts are basic to an understanding of the rigorous process used in developing this guideline, they are explained in detail in this introductory section.

The term research evidence refers to the research-based body of knowledge existing for a specific prevention approach. This information is gained from scientific investigations that range in design rigor from experimental to quasi-experimental to nonexperimental. The term practice evidence describes information gained from prevention practice cases, which is generally presented in the form of well-designed and -executed case studies that include process evaluation information on program implementation and procedures.

Each of the prevention approaches described in this guide includes at least one shaded box that presents information on levels of evidence. These boxes highlight the consensus of the Expert Panel on conclusions that can reasonably be drawn from an analysis of the research and/or practice evidence for each approach. They also indicate the strength of the level of cumulative evidence supporting the conclusions. The criteria for assigning levels of evidence are shown in the following boxes. The first three categories for level of evidence indicate the extent of research and practice evidence for rating the varying degrees of confirmation of positive effect. The fourth category applies to research and practice evidence indicating that a prevention approach is ineffective.

Strong Level of Evidence

Application. This level of evidence means that practitioners can use a prevention approach with the most assurance that the approach can produce the particular effect specified in the evidence statement.

Medium Level of Evidence

Application. This level of evidence means that although the number or rigor of the studies reviewed is limited at this time, there is still substantial support for a prevention approach's ability to produce the particular effect specified in the evidence statement. Practitioners can proceed, but should exercise discretion in application and in assessment of process and outcomes.

Suggestive but Insufficient Evidence

This category is used to describe research and/or practice evidence that (1) is based on a plausible conceptual model or on previous research and (2) is being demonstrated in rigorous evaluation studies or appropriate intervention programs currently in process. One of two conditions typically causes evidence to be described as suggestive but insufficient:

a. In the first condition, the evidence, although limited, appears to support a conclusion, but additional research is needed to fully support the conclusion. This condition often applies to areas in which there has been little study, such as those that are not easily researched or new areas of study.
b. A second condition involves equivocal results. In this condition, a specific conclusion is supported in some studies but is not supported in others.

Application. This level of evidence means that the prevention approach has shown promise for the particular effect specified, but should be regarded as not well documented. Practitioners should be cautious about undertaking approaches with this level of evidence. However, depending on local circumstances, should the approach fit the situation and merit adoption, special attention should be given to its systematic testing and documentation.

Substantial Evidence of Ineffectiveness

This category describes research and practice evidence demonstrating that a prevention approach is not effective. The criterion for inclusion in this category is the absence of a statistically significant effect or the observation of a statistically significant negative effect in a majority of well-executed studies, including at least two quantitative studies with sample sizes sufficient to test for the significance of the effect.

Application. This level of evidence means that the approach has not demonstrated the intended results or has shown negative findings for the particular effect specified. Practitioners should avoid these approaches because they offer no promise of success at this time.

## Using Levels of Evidence in Program Planning

Because prevention activities vary in their emphasis, scope, and content, no two research studies or practice cases are the same. As they differ in the subjects of evaluation and in the methods used, it is difficult to reach a single conclusion about a particular approach. Additionally, there may be varying levels of evidence for different desired results of a prevention approach, as shown by similar findings from more than one study. Therefore, more than one evidence statement may be made to identify and rate conclusions that can be drawn from evidence available on a single approach. For instance, studies may show that a prevention approach has strong evidence for attaining a desired effect in the short term, but suggestive but insufficient evidence for sustaining that effect over time.

The prevention approaches presented in this guide should be considered in light of local circumstances; it may not be feasible to implement only those approaches with a strong level of evidence. Local needs, interests, resources, and abilities - as well as the level of evidence - must all be considered when planners and practitioners make program development choices.