# The Scope of this Guideline

Preventing Substance Abuse Among Children and Adolescents: Family-Centered Approaches focuses on research and practice evidence for a select number of approaches to the prevention of family-related problems. The criteria used for inclusion of studies in this guideline excluded some research and practice evidence. Although other conceptual or practice approaches do exist, sufficient documentation of their use is not yet available. The guideline describes the following three prevention approaches:

1. Parent and Family Skills Training
2. Family In-Home Support
3. Family Therapy

This practitioner's guide summarizes much of the information in the guideline and highlights practical information that is most useful to those directly involved in planning and implementing prevention programs. A brochure-length parent and community guide was also developed to provide a brief overview of substance abuse problems and courses of action for concerned citizens, and to offer tips for becoming involved in family-centered prevention.