# PEPS Series Goals

The primary goal of PEPS is to develop a systematic and consistent process for improvement of substance abuse prevention practice and research. Its objectives are to

- Synthesize research and practice evidence on selected topics
- Present recommendations for effective substance abuse prevention strategies in versions suitable for several target audiences
- Ensure that PEPS products receive optimal dissemination among target audiences
- Monitor the usefulness and relevance of PEPS products
- Identify areas in which additional research is needed

Although lessons from available science are distilled and specific recommendations are made, this guideline is not a "how-to" handbook, nor is it a prescriptive prevention planning guide. Audiences for PEPS products include State prevention agencies, other Federal and State authorities, and community-based organizations addressing the problems of substance abuse or serving high-risk populations. Therefore, targeted users of the PEPS guidelines include policy analysts and decisionmakers, who need sound data to justify funding for prevention planning; State agency and community-based administrators and managers, who will find the series useful in allocating resources and planning programs; researchers, who will receive guidance on the need for future studies; and practitioners, who will find recommendations for programming options that are most appropriate for the populations they serve.