# The PEPS Development Process

The development of a PEPS guideline begins with the deliberations of a Planning Group composed of nationally known researchers and practitioners in the field of substance abuse prevention. With input from their colleagues in the field, these experts identify a topic area that meets pre-established criteria for developing a guideline. A Federal Resource Panel (FRP) with representatives from appropriate Federal agencies then convenes to discuss the proposed content of the guideline. The FRP, taking into consideration recommendations from CSAP and the PEPS Planning Group, identifies those experts in the field best suited to serve on an Expert Panel for the chosen topic.

Once formulated, the Expert Panel meets to determine the scope of the problem to be addressed in the guideline. The PEPS staff conducts exhaustive searches for relevant research and practice information, guided by the knowledge of the Expert Panel and its Chair. The studies and practice cases found are extensively analyzed and their findings compiled and presented in draft form according to the similarity of the prevention approaches used.

A subpanel of selected Expert Panel members then meets to apply the PEPS Rules of Evidence (described later in this section) to formulate summary judgments on the quality of the research and practice evidence, by approach, and to develop recommendations for the prevention field. This draft is reviewed by the full Panel. A revised version of the guideline, including the revisions of the Expert Panel, is distributed for an extensive review by the field. The critique and analysis received are used to further refine and increase the accuracy, readability, and presentation of the guideline.