# About This Guideline

The Prevention Enhancement Protocols System (PEPS) is a systematic and analytical process that synthesizes a body of knowledge on specific prevention topics. It was created by the Division of State and Community Systems Development of CSAP/SAMHSA primarily to support and strengthen the efforts of State and territorial agencies responsible for substance abuse prevention activities. The PEPS program is CSAP's response to the field's need to know "what works" and is an acceptance of the responsibility to lead the field with current information supported by the best scientific knowledge available.

This second guideline in the PEPS series summarizes state-of-the-art approaches and interventions designed to strengthen the role of families in substance abuse prevention. This topic was chosen in response to the field's expressed need for direction and in recognition of the important role of the family as the first line of defense against the dangerous, insidious, and addictive consequences of substance abuse.